# Personal Haplotype Questions

Can you please help me determine what region of the world my haplotype belongs to?

The National Center for Biotechnology Information (NCBI), provides computer access to genetic databases such as the GenBank DNA sequence database and the OMIM database of research information on genetic disorders. We are unable to advise you on personal genetic issues. Your best option would be to send your question to the lab that conducted your DNA test.

You may also wish to view the Alliance of Genetic Support Groups (http://www.geneticalliance.org) website, or contact them at 1-800-336-GENE or 202-966-5557

The GeneClinics (http://www.geneclinics.org/) Website has information relating genetic testing to the diagnosis, management, and genetic counseling of individuals and families with specific inherited disorders.

In case you have not already done so, you may also want to search two of the databases available on our website, OMIM (http://www.ncbi.nlm.nih.gov/entrez/query.fcgi?db=OMIM) and PubMed (http://www.ncbi.nlm.nih.gov/entrez/query.fcgi?db=PubMed). OMIM contains information on genetic diseases, while PubMed can perform specific searches of biomedical literature. Although both are designed for scientists and health professionals, many laypersons find them useful. (2/15/05)