# Information about Haplotypes

What is the link between SNPs and Haplotypes?

If your question is “What is the definition of haplotyopes in terms of SNPs?” here is the answer:

The word "Haplotype" has two definitions. The first definition is the one most people think of —a haplotype is the genetic constitution of an individual chromosome (in diploid species); one member of a pair of alleles for each loci.

When haplotypes are defined with relation to SNPs, the definition changes: a haplotype is a set of SNPs found to be statistically associated on a single chromatid. That is, adjacent SNPs that are inherited together on the basis of linkage disequilibrium. A good site to go to for a more detailed definition is the International HapMap Project (http://www.hapmap.org/whatishapmap.html.en) (11/13/06)

What is a Haplotig?

A Haplotig is a "contig of clones with the same haplotype". You can find the original reference to this word in Genome Biology 2007, 8:R114, which is available online (http://genomebiology.com/2007/8/6/R114). (7/13/07)