# Human Gene Nomenclature

Is there official nomenclature for human genes?

[underlined: The] [underlined: H][underlined: uman] [underlined: G][underlined: ene] [underlined: N][underlined: omenclature] [underlined: C][underlined: ommittee] (http://www.genenames.org/) (HGNC) is part of the Human Genome Organization (HUGO), and has established official, unique nomenclature for human genes. If a gene lacks official nomenclature, the research community is encouraged to use the Nomenclature Committee webform to submit a proposed gene symbol and name. Guidelines (http://www.genenames.org/guidelines.html) for naming are provided. (09/20/07)