# General Information about dbSNP, Single Nucleotide Polymorphisims, and Genetics

This section contains FAQs that provide general information about SNPs, dbSNP as a database, and general scientific knowledge FAQs that range from the possible integration of SNP data and phenotype data, to the theory of evolution and resources helpful in interpreting personal genetic data.

To begin searching this section of the dbSNP FAQ Archive, you can either:

Enter your search word(s) text in the text box at the top of the page and click on the “Search” button,

OR

Clickon any of the “dbSNP General Information” sub-categories listed in the “Contents” section below to navigate to the sub-category of your choice.