# Genome Workbench SNP Tools (GST) Quick Start

This Quick Start guide is intended for the users of the NCBI Genome Workbench (http://www.ncbi.nlm.nih.gov/projects/gbench/) SNP Tools, and contains information and step by step instructions for an array of topics that include using GST for the first time and learning how to use specific GST features, GST functionality and application of GST to your specific research needs.

As the GST Quick Start guide is arranged as a topical reference, you don’t have to read it from beginning to end to find specific pieces of information. If there are topics you’d like to see in this guide that are not currently included, please email snp-admin.

To begin searching this section of the dbSNP FAQ Archive, you can:

Enter your search word(s) text in the text box at the top of the page and click on the “Go” button

OR

Click on any of the “Genome Workbench SNP Tools” sub-categories listed in the “Contents” section below to navigate to the sub-category of your choice. Once you are in the sub-category, you will be presented with a grey box containing the questions for the sub-category you selected. Clicking on a question in this list will allow you to navigate to the answer.