# Direct Queries of dbSNP’s Database Server

Can I query your database server directly?

The NCBI database group policy forbids outside access to dbSNP.