# dbSNP Data Content Information

This section contains FAQs that provide information about the data contained in dbSNP, from data origins and quality control, to database statistics and data storage information. There are FAQs that describe the classes of genetic variations included in dbSNP, and the sequence notation used for the data housed in dbSNP, as well as FAQs that answer questions about submitted data content, from strain data included in dbSNP, to population diversity data. There are also FAQs that answer questions about how dbSNP computes data – everything from determining ancestral alleles to calculating a double hit SNP.

To begin searching this section of the dbSNP FAQ Archive, you can:

Enter your search word(s) text in the text box at the top of the page and click on the “Go” button

OR

Click on any of the “dbSNP Data Content” sub-categories listed in the “Contents” section below to navigate to the sub-category of your choice. Once you are in the sub-category, you will be presented with a grey box containing the questions for the sub-category you selected. Clicking on a question in this list will allow you to navigate to the answer.