# dbSNP Data Storage Information

Are all SNP records stored in dbSNP, or are all SNP records embedded within GenBank annotation, and dbSNP accesses the records from there?

All SNP records are stored primarily in dbSNP. GenBank annotates its records using the information found in dbSNP records.