# References

1 Marth GT, Czabarka E, Murvai J, Sherry ST. (2004) The allele frequency spectrum in genome-wide human variation data reveals signals of differential demographic history in three large world populations. Genetics. Jan;166(1):351-372