# Association Studies

I am designing a SNP association study, and am looking for control samples that are already available. Does NIH have control samples that I can access?

Association study data are available through dbGaP (http://www.ncbi.nlm.nih.gov/sites/entrez?db=gap) .The left sidebar has a link to the dbGaP FTP site where you can download public access data, and where users with the appropriate permissions can download controlled access data.

Please contact dbgap-help@ncbi.nlm.nih.gov if you have any questions.(01/08/08)