# Citing dbSNP

This section contains FAQs that describe how to cite dbSNP and SNP data in a publication.

To begin searching this section of the dbSNP FAQ Archive, you can:

Enter your search word(s) text in the text box at the top of the page and click on the “Go” button

OR

Click on any of the “Citing dbSNP” sub-categories listed in the “Contents” section below to navigate to the sub-category of your choice. Once you are in the sub-category, you will be presented with a grey box containing the questions for the sub-category you selected. Clicking on a question in this list will allow you to navigate to the answer.