# dbSNP Database Statistics

I would like to cite the number of SNPs reported today in the human genome. Can you point me to a good reference?

Go to the dbSNP summary page (http://www.ncbi.nlm.nih.gov/projects/SNP/snp_summary.cgi), and scroll down to the BUILD STATISTICS table. (7/6/07)