# dbSNP Creation Date Information

When was dbSNP created and released to the public?

dbSNP was first created and released to public in September of 1998. (11/10/05)