# Using Images from NCBI Sites

I would like to include images from NCBI web pages on a free-use, non-commercial web site. Am I allowed to use NCBI images in such a way?

Please see the NCBI Copy Right notice (http://www.ncbi.nlm.nih.gov/About/disclaimer.html). You can use the materials as long as you cite the source. (12/15/06)