# The dbSNP Build Process

This section contains FAQs that provide general information about how a new dbSNP build is triggered, how builds are scheduled, the difference between a dbSNP build and a genome build, the data changes that can occur between builds, as well as FAQs that will show you how to find old build data, or the date of an old build. There are FAQs in this section that describe sequence notation and explain strand orientation, and describe portions of the mapping process in detail. There are also FAQs in this section that can help you find missing or merged SNPs, tell you why a SNP merged or split, answer questions about submitted data or explain how dbSNP computes data – from determining ancestral alleles to calculating a double hit SNP.

To begin searching this section of the dbSNP FAQ Archive, you can:

Enter your search word(s) text in the text box at the top of the page and click on the “Go” button

OR

Click on any of the “dbSNP Build Process” sub-categories listed in the “Contents” section below to navigate to the sub-category of your choice. Once you are in the sub-category, you will be presented with a grey box containing the questions for the sub-category you selected. Clicking on a question in this list will allow you to navigate to the answer.