# dbSNP and Haplotype Tagged SNPs

refSNP cluster reports used to have a link to “haplotype tagged SNP” data, but now I can’t find it. Where is it?

We do not currently have “Haplotype tagged SNP” data and therefore have removed the 'Haplotype tagged' search filters from our web pages. We anticipate that we may get “Haplotype tagged SNP” data in the future, and will make them publicly available at that time. (02/27/08)