# Using Old vs. New Build Data

Some of my SNPs are mapped to build 126, and some to build 127. Is it important that all my SNPs should be mapped to either build 126 or 127?

Use the latest build — it will have improved mapping and corrections for past errors.(9/28/07)