# Lag Time between dbSNP Website and FTP Site Following Build

rs4646149 shows the submission of ss69370884 in build 127 on the website, but there's no record of that submission in the dbSNP FTP SubSNP.bcp file.

ss69370884 was submitted (http://www.ncbi.nlm.nih.gov/SNP/snp_ss.cgi?subsnp_id=69370884) on March 22, 2007, but the SubSNP.bcp file on FTP site was created on March 6, 2007. Build 127 was released on March 8, 2007.

In general, new submitted SNPs (ss) are made public more frequently than there are SNP build releases so submitters can see their submissions more quickly(without having to wait months for a new build release). In the past, new submitted SNPs were not clustered until the new build.

Beginning in May 2007, however, we cluster the new submitted SNPs as they arrive, so when these submitted SNPs (including ss69370884) are made public they also show up in their clusters, as you have observed. All the table .bpc files, however, are created only once per build, so that is why you don't see this submitted SNP in the .bcp files. (7/2/07)