# Heterozygosity Data

How does dbSNP compute average heterozygosity?

A document describing the computation of average heterozygosity and standard error for dbSNP RefSNP clusters is available online (http://www.ncbi.nlm.nih.gov/SNP/Hetfreq.html) (04/05/06)

We have sequenced a cDNA containing a base change that corresponds to a SNP in the SNP database, yet dbSNP shows no heterozygosity data for this SNP. Why is this?

We compute heterozygosity at dbSNP based on submitted allele frequency for the SNP. In the case of an example SNP, say rs4779794, the frequency data were not directly submitted, so we were unable to compute the heterozygosity value.