# What are the Sequin Wizards?

The Sequin Wizards will guide you in preparing your submission file for specific types of sequence submissions in the NCBI Sequin Submission Tool (http://www.ncbi.nlm.nih.gov/projects/Sequin/). The wizards are designed to capture all the required source information and will provide some assistance with annotation. Currently, there are wizards available for the following types of submissions:

- Viruses
- Uncultured Samples
- rRNA-ITS-IGS Sequences
- Intergenic Spacer Sequences
- Microsatellite Sequences
- D-Loop/Control Region Sequences

Prior to using the Wizards, make sure you have:

- Removed all contaminating vector sequence
- Quality trimmed your sequences
- Checked 16S ribosomal RNA submissions for anomalies using a chimera check tool. Anomalous sequences should be removed from your FASTA file.