# Submission Wizard for D-loops and Control Regions

## Purpose

The D-loop and Control Region Submission Wizard is for submitting mitochondrial D-loop and Control Region sequence submissions only. This wizard will guide you in providing all of the necessary source information for these sequences and will provide assistance and direction with feature annotation. Examples of source information are provided.

## Wizard Import Nucleotide Sequences

Requirements: The D-loop and Control Region Submission requirements are listed in the Sequences tab of the Wizard Import Nucleotide Sequences dialog box.

Sequence Format: You may import your sequences in FASTA format or you may import an alignment. Use the Import Nucleotide FASTA button to import your properly formatted FASTA file. For help with how to format the FASTA file click the FASTA Format Help button. The Sequences tab will display the information about the imported sequence(s). Please check the number of sequences, Sequence IDs (SeqIDs) and length of each sequence to make sure this information is correct. You may also import a nucleotide alignment file in any of the Sequin compatible formats (fasta+gap, Nexus, Phylip). See examples of these formats here (http://www.ncbi.nlm.nih.gov/Sequin/QuickGuide/sequin.htm#alignmentformats).

If the sequences contain a significant number of ambiguous bases near the 5' or 3' end, you may be prompted to trim or remove these sequences from your submission.

Trim Vector Contamination: It is highly recommended that you perform a vector screen (http://www.ncbi.nlm.nih.gov/Sequin/sequin.hlp.html#VectorScreen) on your sequences and trim vector contamination by clicking the Vector Trim Tool button.

Delete Sequences: You can remove sequences from your submission using the Sequence Deletion Tool (http://www.ncbi.nlm.nih.gov/Sequin/sequin.hlp.html#SequenceDeletionTool) under the Edit Menu. This tool will assist you in removing any sequences from your file that you need to delete or that do not meet GenBank minimum sequence length requirements.

## Sequencing Method

If you are submitting over 500 sequences or your sequences were generated using next-generation sequencing technology, the information in this form is required.

Sequencing Method: Use the check boxes at the top of the form to select the sequencing technology type(s) used to obtain the sequences. Multiple types can be selected, if appropriate. If you used technology that is not listed in the form, please select other and use the free text box to provide the information.

Assembly Program: After selecting the sequencing technology, select the radio button to indicate if your sequences are raw sequence reads or sequence assemblies. If you are submitting assemblies using next-generation sequencing technology, the name of the assembly program and program version or date the assemblies were made are required in the free text boxes. If multiple assembly programs were used, Click on Add More Assembly Programs and complete the provided spreadsheet.

Raw sequence reads from next generation sequencing technologies should not be submitted to GenBank.

## Submission Type

If you are submitting more than one sequence, you will be prompted to select the type of submission you are creating. If you select a set, all of the sequences in the set must have the same release date. The following submission types are available in the D-loop Wizard:

- Pop set (Population study): a set of sequences that were derived by sequencing the same gene from different isolates of the same organism.
- Phy set (Phylogenetic study): a set of sequences that were derived by sequencing the same gene from different organisms.
- Mut set (Mutation study): a set of sequences that were derived by sequencing multiple mutations of a single gene.
- Batch: related sequences that are not part of a population, mutation, or phylogenetic study. The sequences should be related in some way, such as coming from the same publication or organism. This option will not be available if you imported an alignment.

## D-Loop Wizard Source Information

Requirements: All sequences must have an organism name and unique source information. Use the buttons below the table to add a column to the table, as appropriate. If you are submitting sequences from the same type of organism, you will need to provide one of the following: isolate codes, haplotypes, specimen-voucher, breed, or cultivars. There must be unique source information for each sequence to pass this dialog.

How to add source information: There are three ways to add the source information: 1) directly type into this form, 2) import a tab-delimited source table, or 3) automatically populate the form if source information was included in the FASTA definition lines.

You can set the same source qualifier value for all sequences by filling in the top row of boxes and using the appropriate Apply button. Use the Copy from SeqID button to apply the sequence IDs to the qualifier indicated in this table if this information was used as the sequence IDs in the original FASTA file.

Click on the Source Table Help button to open a text dialog with information on making a tab-delimited source table.

If you entered all required source information in the FASTA definition lines, minimal input will be necessary on this form.

Errors: Any problems or missing information will be listed on the right side of the form. If you have made any changes on this form, please use the Recheck Errors button to validate the new information. Use the Show only sequences with errors radio button to list only those sequences that did not pass the validation.

Are you unable to pass the Source Information window? If you have not provided some required source information, the issue will be listed in the ***Problems*** column. After fixing any problems, click the Recheck Errors Button to determine if all issues have been fixed. You may display only the entries with problems by selecting the radio button next to Show only sequences with errors.

Do you not see a source qualifier in the table that you want to use in your submission? You may add columns for some commonly added source qualifiers using the buttons below the table. Other optional modifiers can be added to provide additional information using the “Apply/See More Source Information” button or “Import Source Table” button. A window with instructions for creating a source table can be viewed by clicking Source Table Help.

Did you have source information in your FASTA file that is not displayed in this table? This table only displays the required source qualifiers for each type of submission. It does not display all source information. If your FASTA definition lines were correctly formatted, the extra source information you provided in the FASTA definition lines will be imported. You will be able to review this information in the record viewer.

## D-Loop Wizard Annotation

Use this dialog to select the feature(s) in your sequences. If your sequences contain more than the D-loop/Control Region, select D-loop/Control Region and other features (tRNA/rRNA).

## D-Loop Wizard Features

You will be prompted for further information if you selected D-loop/Control Region and other features (tRNA/rRNA). If you do not know the nucleotide spans of the features in your sequences, select No in this dialog and then select the number of other features in your sequences. The D-Loop wizard will only assist with annotating up to four features. If you do know the nucleotide spans of the features in your sequences, select yes in this dialog. A text dialog will open with instructions for importing a five-column, tab-delimited table containing the feature locations. You may also apply annotation using the Annotate (http://www.ncbi.nlm.nih.gov/Sequin/sequin.hlp.html#AnnotateMenu-Features) menu options in the record viewer. Alternately, if you imported an alignment you may use Feature Propagate (http://www.ncbi.nlm.nih.gov/Sequin/sequin.hlp.html#FeaturePropagate) or the Alignment Assistant (http://www.ncbi.nlm.nih.gov/Sequin/sequin.hlp.html#AlignmentAssistantFeaturesMenu) to add feature annotation to your submission.

## D-Loop Wizard Feature Annotation

If you indicated that you do not know the nucleotide spans for the features in your sequences, this dialog will collect information for what your sequences contain and create a misc_feature that spans the length of the sequences in your submission. Select the features in your sequences starting at the 5’ end as feature 1. If your sequences contain a tRNA or rRNA, click the radio button next to tRNA or rRNA and use the pull-down list to select the appropriate tRNA or rRNA. You may only select D-loop or Control Region once.