# The Design of this User’s Guide

This User’s Guide is designed to be a practical, plain language guide for the beginner— or for anyone who wants basic instructions for any of the steps you must perform when you submit using the Sequin Wizards.

Each major section in this User’s Guide provides instructions for using each Sequin Wizard Submission Tool. In each section you will find a summary of purpose for each wizard and step-by-step instructions to guide you through the steps in the wizard.