# Submitting Multiple Sequences as a Set

What is the difference between a batch and a set?

A Set is a group of sequences of the same gene and/or locus that are part of a population, mutation, phylogenetic or environmental study, and are published together in the same journal article. The sequences in a Set will be processed together as a unit and will be accessible together using Entrez PopSet (http://www.ncbi.nlm.nih.gov/popset).

A Batch is a group of sequences that are related in some way, but from different genes and/or loci, such as coming from the ame organism or being published together in the same journal article.

When can multiple sequences be submitted together as a set?

- Members of a sequence set are published together in the same journal article, and are used to analyze the relatedness of a (sequence) population by analysis of the same gene or locus.
- Below is a list of standard set types submitted to GenBank:
  - Population study: a set of sequences that were derived by sequencing the same gene from different isolates of the same organism.
  - Phylogenetic study:a set of sequences that were derived by sequencing the same gene from different organisms.
  - Mutation study:a set of sequences that were derived by sequencing multiple mutations of a single gene.
  - Environmental samples:a set of sequences that were derived by sequencing the same gene from a population of unclassified or unknown organisms.

In all the cases listed above, each sequence set is handled as a single submission, but each sequence submitted in a set will receive its own Accession number, and can be annotated independently.

Sequence sets can be submitted to GenBank via Sequin (http://www.ncbi.nlm.nih.gov/books/n/helpgbank/gbankquickstart.Submitting_Sequences_usi/#gbankquickstart.Submission_using_Sequin) or BankIt (http://www.ncbi.nlm.nih.gov/books/n/helpgbank/gbankquickstart.Submitting_Sequences_usi/#gbankquickstart.Submission_using_BankIt).

How do I submit multiple sequences as a set?

To submit a group of sequences as a set, do the following:

- Sequin:
  1 Fill out the Sequin Submitting Authors form.
  2 Select the set type on the Sequence Format Form (see the answer to “When can multiple sequences be submitted together as a set?).
  3 Sequin will prompt you to enter the data appropriate to the set.
- BankIt: Once you have completed steps 1 (Contact) and 2 (Reference) of the BankIt submission process, step 3 (Submission Type) will give you a choice as to the submission type you intend to submit:
  1 If you intend to submit a set, select the radio button in front of “Set”.
  2 A question asking the number of sets you intend to submit will appear as will a list of set types (population/phylogenetic/mutation/environmental).
  3 Enter the total number of sets you intend to submit. (Note: you can only send one set per BankIt submission, so you will have to open a BankIt submission session for each additional set you intend to submit.).
  4 Select the radio button in front of the set type you intend to submit.
  5 From this point, BankIt will ask you for appropriate source and feature data for the set type you wish to submit.