# Setting Release Dates for your Submission

Can I submit now and have my sequences withheld from the database until a later date?

As you prepare your submission using Sequin or BankIt, you will be allowed to specify a future release date for the sequence(s) you are submitting. GenBank will hold your sequence(s) from public view until this date or when the accession numbers or sequence data are published, whichever is first.

Can I ask for an extension of a release date? The paper describing the sequence(s) I submitted will not be published by the release date I specified in my submission.

If the paper describing your sequence will not be published by the release date specified in your submission, email GenBank at gb-admin@ncbi.nlm.nih.gov and request an extension of the release date for the accession number(s) involved. Provide a specific release date; we cannot withhold a sequence indefinitely pending publication.

Note: A request for the extension of a release date must be submitted to GenBank well in advance of the original release date specified in your submission.

If the paper describing my sequence is accepted before the release date I provide, how do I ask GenBank to release the sequence(s)?

To request the release of a sequence record prior to the release date specified in your submission, contact the GenBank annotation staff at gb-admin@ncbi.nlm.nih.gov. Include in your request the accession number or range of accessions that you wish to have released and the relevant publication details.

I found a GenBank accession number in a publication, but I can’t find the corresponding sequence for it in GenBank. How do I get the sequence released so I can see it?

In order to release the accession(s) you need to public view, we will need to independently verify that the accessions in question have indeed been published. What you can do to help us do this is to send either the:

- The citation for the article in which the accession appears. Please include a PDF if possible.

OR

- The PubMed ID (PMID) number for the article in which the accession appears to info@ncbi.nlm.nih.gov

.