# Sending your Submission to GenBank

## Problems Sending Files by email

I have tried to email my large Sequin file and it will not go through. Do you have a size limit? How do I transmit the file to you?

We don’t have a maximum size limit. However, as many email systems will truncate large messages, we suggest you send us your file(s) using SequinMacroSend (http://www.ncbi.nlm.nih.gov/LargeDirSubs/dir_submit.cgi) if you are having trouble sending us a file by email.

SequinMacroSend was designed for uploading large .sqn files directly to GenBank using a web-interface rather than sending large email attachments.

Fill in the information on the SequinMacroSend (http://www.ncbi.nlm.nih.gov/LargeDirSubs/dir_submit.cgi) form (the form is located at the bottom of the SequinMacroSend page), upload your prepared .sqn file, and the submission will be sent directly to the GenBank submission staff.