# GenBank Submission Resources Quick Start

This guide will help you begin the GenBank submission process. It is arranged as a topical reference, so you do not have to read from beginning to end to find specific pieces of information. Each question/answer unit in this Quick Start will:

- Provide information that will address common GenBank submission questions
- Provide links to appropriate GenBank resources
- Provide links to specific GenBank user documentation that will address the question in greater detail.

Although most general GenBank submission questions should be addressed by the information contained in this document, if you are unable to find the information you are looking for, contact info@ncbi.nlm.nih.gov .

To begin searching this section of the GenBank Submission Resources Quick Start, you can either:

Enter your search word(s) text in the text box at the top of the page and click on the “Go” button,

OR

Click on any of the “GenBank Submission Resources Quick Start” sub-categories listed in the “Contents” section below to navigate to the sub-category of your choice.