# The “Set/Batch” Page

This page will appear after the “Nucleotide” page if you entered more than one sequence. If you entered a single sequence in the “Nucleotide” page, the “Set/Batch” page will not appear, and you will go directly to the next page of the form.

Select one of the set types listed and defined in the Set/Batch page to identify what kind of set you are submitting, or select the “Batch” option. Select the “Batch option if the nucleotide sequences you are submitting are not of the same gene, but are related because they may be discussed in the same publication or are from the same organism.