# Entrez Direct Examples

Some early EDirect examples required post-processing with shell script:

  start=$(( start + 1 ))  stop=$(( stop + 1 ))

or awk commands:

  awk -F '\t' -v 'OFS=\t' '{print $1, $2+1, $3+1}'

to increment 0-based sequence coordinates so that the proper region was retrieved:

  efetch -db nuccore -id $accn -format fasta -seq_start $start -seq_stop $stop

This led to -element derivatives that could do simple adjustments within an xtract command:

  -element ChrAccVer -inc ChrStart -1-based ChrStop

and to efetch arguments that could take 0-based coordinates directly:

  efetch -db nuccore -id $accn -format fasta -chr_start $start -chr_stop $stop

These helped eliminate the need for scripts to perform otherwise trivial modifications on extracted data.

More recent work allows easier after-the-fact numeric and substring matching using filter-columns:

  filter-columns '10 <= $2 && $2 <= 30 && $5 ~ peptide'

and text and number modification using print-columns:

  print-columns '$1, $2+1, $3-1, "\042" $4 "\042", tolower($5), log($3), total += $2'

Both scripts accept column designators in an argument and pass them to internal awk commands. The NF (number of fields) and NR (current record number) built-in variables can also be used, as can YR (for year) and DT (for date in YYYY-MM-DD format).

## PubMed

### Author Frequency

Who are the most prolific authors on rattlesnake phospholipase?

  esearch -db pubmed -query \    "crotalid venoms [MAJR] AND phospholipase [TIAB]" |  efetch -format xml |  xtract -pattern PubmedArticle \    -block Author -sep " " -tab "\n" -element LastName,Initials |  sort-uniq-count-rank

Placing author names on separate lines allows sort-uniq-count-rank to produce a frequency table:

  87    Lomonte B  77    Gutiérrez JM  64    Soares AM  53    Marangoni S  43    Giglio JR  39    Bon C  ...

### Publication Distribution

When were the most papers about Legionnaires disease published?

  esearch -db pubmed -query "legionnaires disease [TITL]" |  efetch -format docsum |  xtract -pattern DocumentSummary -element PubDate |  cut -c 1-4 |  sort-uniq-count-rank

In this case sort-uniq-count-rank reports the number of selected papers per year:

  173    1979  102    1980  96     1978  92     1981  66     1983  ...

Using ‑year "PubDate/*" on a PubmedArticle record takes the first four-digit number it encounters, and the result does not need to be trimmed:

  esearch -db pubmed -query "legionnaires disease [TITL]" |  efetch -format xml |  xtract -pattern PubmedArticle -year "PubDate/*" |  sort-uniq-count-rank

### Treatment Locations

What is the geographic distribution of sepsis treatment studies?

  esearch -db pubmed -query \    "sepsis/therapy [MESH] AND geographic locations [MESH]" |  efetch -format xml |  xtract -pattern PubmedArticle \    -block MeshHeading -if DescriptorName@Type -equals Geographic \      -tab "\n" -element DescriptorName |  sort-uniq-count-rank

This returns the number of articles ranked by country or region:

  660    United States  250    Spain  182    Germany  168    India  155    Taiwan  139    Japan  126    China  124    France  123    Europe  ...

Note that England and United Kingdom will appear as two separate entries.

### Indexed Date Fields

What date fields are indexed for PubMed?

  einfo -db pubmed |  xtract -pattern Field \    -if IsDate -equals Y -and IsHidden -equals N \      -pfx "[" -sfx "]" -element Name \      -pfx "" -sfx "" -element FullName |  sort -k 2f | expand

Indexed dates are shown with field abbreviations and descriptive names:

  [CDAT]  Date - Completion  [CRDT]  Date - Create  [EDAT]  Date - Entrez  [MHDA]  Date - MeSH  [MDAT]  Date - Modification  [PDAT]  Date - Publication

Two other date fields have the IsHidden value set to "Y":

  [EPDT]  Electronic Publication Date  [PPDT]  Print Publication Date

### Digital Object Identifiers

How are digital object identifiers obtained from PubMed articles?

  esearch -db pubmed -query "Rowley JD [AUTH]" |  efetch -format xml |  xtract -head '<html><body>' -tail '</body></html>' \    -pattern PubmedArticle -PMID MedlineCitation/PMID \      -block ArticleId -if @IdType -equals doi \        -tab "" -pfx '<p><a href="' -sfx '">' -doi ArticleId \        -tab "\n" -pfx '' -sfx '</a></p>' -element "&PMID" |  transmute -format

The ‑doi command extracts the DOIs and constructs URL references. The ‑pfx and ‑sfx arguments used here enclose each PMID with a clickable link to its DOI:

  <?xml version="1.0" encoding="UTF-8" ?>  <!DOCTYPE html>  <html>    <body>      <p>        <a href="https://doi.org/10.1038%2Fleu.2013.340">24496283</a>      </p>      <p>        <a href="https://doi.org/10.1073%2Fpnas.1310656110">23818607</a>      </p>      ...    </body>  </html>

### Reference Formatting

How were references in the main EDirect documentation page formatted?

  efetch -db pubmed -format docsum -id 8743683 31600197 17971238 \    23175613 11449725 26931183 31738401 31114887 14728215 29390967 |

Relevant document summary fields were collected with:

  xtract -set Set -rec Rec -pattern DocumentSummary \    -sep ", " -sfx "." -NM Name -clr \    -sfx "." -SRC Source -clr \    -pfx ":" -PG Pages -clr \    -pfx "(PMID " -sfx ".)" -ID Id -clr \    -group ArticleId -if IdType -equals doi \      -pfx "https://doi.org/" -sfx "." -DOI Value -PG "(.)" -clr \    -group DocumentSummary \      -wrp Sort -lower "&NM" \      -wrp Name -element "&NM" \      -wrp Title -element Title \      -wrp Source -element "&SRC" \      -wrp Year -year PubDate \      -wrp Pages -element "&PG" \      -wrp DOI -element "&DOI" \      -wrp Id -element "&ID" |

This generated intermediate XML with partial formatting:

  ...  <Rec>    <Sort>wei ch, allot a, leaman r, lu z.</Sort>    <Name>Wei CH, Allot A, Leaman R, Lu Z.</Name>    <Title>PubTator central: automated concept ... full text articles.</Title>    <Source>Nucleic Acids Res.</Source>    <Year>2019</Year>    <Pages>.</Pages>    <DOI>https://doi.org/10.1093/nar/gkz389.</DOI>    <Id>(PMID 31114887.)</Id>  </Rec>  ...

References were sorted by the first author’s last name:

  xtract -set Set -rec Rec -pattern Rec -sort Sort |

and then printed with:

  xtract -pattern Rec -deq "\n\n" -tab " " -sep "" \    -element Name Title Source Year,Pages DOI Id

followed by manual editing of hyphenated initials:

  ...  Wei C-H, Allot A, Leaman R, Lu Z. PubTator central: automated concept  annotation for biomedical full text articles. Nucleic Acids Res. 2019.  https://doi.org/10.1093/nar/gkz389. (PMID 31114887.)  ...

Using xtract ‑reg and ‑exp regular expressions to guide xtract ‑replace:

  efetch -db pubmed -id 31114887 -format xml |  xtract -pattern PubmedArticle -block Author -deq "\n" \    -element LastName -reg "[a-z .]" -exp "" -replace ForeName

can generate hyphenated initials directly from the PubmedArticle ForeName field:

  <Author>    <LastName>Wei</LastName>    <ForeName>Chih-Hsuan</ForeName>    <Initials>CH</Initials>  </Author>

by removing lower-case letters, spaces, and periods.

## Nucleotide

### Coding Sequences

What are the coding sequences in the Escherichia coli lac operon?

  efetch -db nuccore -id J01636.1 -format gbc |  xtract -insd CDS gene sub_sequence

Sequence under a feature location is obtained with the ‑insd "sub_sequence" argument:

  J01636.1    lacI    GTGAAACCAGTAACGTTATACGATGTCGCAGAGTATGCCG...  J01636.1    lacZ    ATGACCATGATTACGGATTCACTGGCCGTCGTTTTACAAC...  J01636.1    lacY    ATGTACTATTTAAAAAACACAAACTTTTGGATGTTCGGTT...  J01636.1    lacA    TTGAACATGCCAATGACCGAAAGAATAAGAGCAGGCAAGC...

### Untranslated Region Sequences

What are the 5' and 3' UTR sequences for lycopene cyclase mRNAs?

  SubSeq() {    xtract -pattern INSDSeq -ACC INSDSeq_accession-version -SEQ INSDSeq_sequence \      -group INSDFeature -if INSDFeature_key -equals CDS -PRD "(-)" \        -block INSDQualifier -if INSDQualifier_name -equals product \          -PRD INSDQualifier_value \        -block INSDFeature -pfc "\n" -element "&ACC" -rst \          -first INSDInterval_from -last INSDInterval_to -element "&PRD" "&SEQ"  }  UTRs() {    while IFS=$'\t' read acc fst lst prd seq    do      if [ $fst -gt 1 ]      then        echo -e ">$acc 5'UTR: 1..$((fst-1)) $prd"        echo "${seq:1:$((fst-2))}" | fold -w 50      else        echo -e ">$acc NO 5'UTR"      fi      if [ $lst -lt ${#seq} ]      then        echo -e ">$acc 3'UTR: $((lst+1))..${#seq} $prd"        echo "${seq:$lst}" | fold -w 50      else        echo -e ">$acc NO 3'UTR"      fi    done  }  esearch -db nuccore -query "5.5.1.19 [ECNO]" |  efilter -molecule mrna -feature cds -source refseq |  efetch -format gbc |  SubSeq | UTRs

Sequences before the start codon and after the stop codon are obtained with Unix substring commands:

  >NM_001324787.1 NO 5'UTR  >NM_001324787.1 NO 3'UTR  >NM_001324979.1 5'UTR: 1..262 lycopene beta cyclase, chloroplastic/chromoplastic  attatagaaatacttaagatatatcattgccctttaatcatttattttta  actcttttaagtgtttaaagattgattctttgtacatgttctgcttcatt  tgtgttgaaaattgagttgttttcttgaattttgcaagaatataggggac  cccatttgtgttgaaaattgagcagctttctttgtgttttgttcgatttt  tcaagaatataggaccccattttctgttttcttgagataaattgcacctt  gttgggaaaat  >NM_001324979.1 3'UTR: 1760..1782 lycopene beta cyclase, chloroplastic/chromoplastic  attcgacttatctgggatcttgt  ...

### 5-Column Feature Table

How can you generate a 5-column feature table from GenBank format?

  XtoT() {    xtract -pattern INSDSeq -pfx ">Feature " \        -first INSDSeqid,INSDSeq_accession-version \      -group INSDFeature -FKEY INSDFeature_key \        -block INSDInterval -deq "\n" \          -element INSDInterval_from INSDInterval_to \            INSDInterval_point INSDInterval_point \            "&FKEY" -FKEY "()" \        -block INSDQualifier -deq "\n\t\t\t" \          -element INSDQualifier_name INSDQualifier_value  }  efetch -db nuccore -id U54469 -format gb |  transmute -g2x |  XtoT

Exploring the INSDSeq XML hierarchy with a ‑pattern {sequence} ‑group {feature} ‑block {qualifier} construct, and adding proper indentation, can produce feature table submission format:

  >Feature U54469.1  1       2881    source                            organism      Drosophila melanogaster                            mol_type      genomic DNA                            db_xref       taxon:7227                            chromosome    3                            map           67A8-B2  80      2881    gene                            gene          eIF4E  80      224     mRNA  892     1458  1550    1920  1986    2085  2317    2404  2466    2881                            gene          eIF4E                            product       eukaryotic initiation factor 4E-I                            ...

An xml2tbl script containing this xtract command is now included with EDirect.

### WGS Components

How can you get FASTA format for all components of a WGS project?

  GenerateWGSAccessions() {    gb=$( efetch -db nuccore -id "$1" -format gbc < /dev/null )    ln=$( echo "$gb" | xtract -pattern INSDSeq -element INSDSeq_length )    pf=$(      echo "$gb" |      xtract -pattern INSDSeq -element INSDSeq_locus |      sed -e 's/010*/01/g'    )    seq -f "${pf}%07.0f" 1 "$ln"  }  GenerateWGSAccessions "JABRPF000000000" |

returns the expanded list of accessions from the WGS master:

  JABRPF010000001  JABRPF010000002  JABRPF010000003  ...  JABRPF010000061  JABRPF010000062  JABRPF010000063

Piping those accessions to:

  efetch -db nuccore -format fasta

retrieves the individual components in FASTA format:

  >JABRPF010000001.1 Enterococcus faecalis strain G109-2 contig00001, ...  ACACTAATATGTGTCTTTTTAGACACTAGCTCACTAAAAAAAATAGTCATAATTTCTTCATTATTAAAAT  CCAACAATTGTGAAATCAATTTAATATCCGATGCTTTGAAAACAACTTCTCCTTTTAATTTTTTGTAAAT  CGTTGAAGCGGATATTGGTTGCCCGTATGCAGTCATTTCATTTGCCAACCACTCAACATTTTTTCCTTTC  ...

### Proteins in a Region

How do you get the protein records encoded in a specific region of a nucleotide sequence?

  efetch -db nuccore -id NC_015162.1 -format gb -seq_start 9125 -seq_stop 103803 |  xtract -insd CDS protein_id |  cut -f 2 |  efetch -db protein -format fasta

extracts the protein_id accessions and retrieves those proteins in FASTA format:

  >WP_013615770.1 hypothetical protein [Deinococcus proteolyticus]  MTQNASAGLTAETLMTETGLSAAAVRRALKAYDAAFGLEHPTQDGELHLTPAEYDVLRRALQLTGGYAPG  LKLWFGEQQALALSTQPVASPREVQQLSQLYQQVESYRARPPEEPAQTLRALLDQAQALGWSGFWEMGRL  QGAALFVLGVLRFEDGQRAKVSMQTPLSGAEALVLSRGVCALLQRVRTQPGSGQAWSWNEVLLEEVERIL  KDLTE  >WP_013615771.1 hypothetical protein [Deinococcus proteolyticus]  MNKDTNVDTAFAGGFFTTFENGECVFYDADGVCHSVTPDTVAAVVASGTPRDVVALHEDVQGRTDAVAQV  ...

### Reverse Complement GenBank

How do you reverse complement a nucleotide sequence in GenBank format?

  efetch -db nuccore -id J01749 -format gb |  gbf2fsa |  transmute -revcomp |  transmute -fasta -width 50

converts GenBank to FASTA, reverse-complements the sequence, and saves it at the selected 50 characters per line:

  TTCTTGAAGACGAAAGGGCCTCGTGATACGCCTATTTTTATAGGTTAATG  TCATGATAATAATGGTTTCTTAGACGTCAGGTGGCACTTTTCGGGGAAAT  GTGCGCGGAACCCCTATTTGTTTATTTTTCTAAATACATTCAAATATGTA  ...  ACGATGAGCGCATTGTTAGATTTCATACACGGTGCCTGACTGCGTTAGCA  ATTTAACTGTGATAAACTACCGCATTAAAGCTTATCGATGATAAGCTGTC  AAACATGAGAA

### Reverse Complement NCBI2NA

How do you reverse complement a 2-bit encoded nucleotide sequence?

  efetch -db nuccore -id J01749 -format asn |  xtract -pattern Seq-entry \    -group seq -if ncbi2na \      -block inst -LEN length -SEQ -ncbi2na ncbi2na \        -SUB "&SEQ[:&LEN]" -REV -revcomp "&SUB" \        -sep "\n" -fasta "&REV"

expands the NCBI2NA representation to IUPACNA, truncates at the indicated length, reverse-complements that sequence, and saves it at the default 70 characters per line:

  TTCTTGAAGACGAAAGGGCCTCGTGATACGCCTATTTTTATAGGTTAATGTCATGATAATAATGGTTTCT  TAGACGTCAGGTGGCACTTTTCGGGGAAATGTGCGCGGAACCCCTATTTGTTTATTTTTCTAAATACATT  CAAATATGTATCCGCTCATGAGACAATAACCCTGATAAATGCTTCAATAATATTGAAAAAGGAAGAGTAT  ...  GCATAACCAAGCCTATGCCTACAGCATCCAGGGTGACGGTGCCGAGGATGACGATGAGCGCATTGTTAGA  TTTCATACACGGTGCCTGACTGCGTTAGCAATTTAACTGTGATAAACTACCGCATTAAAGCTTATCGATG  ATAAGCTGTCAAACATGAGAA

### Six-Frame Protein Translation

How do you translate all six reading frames of a nucleotide sequence?

  efetch -db nuccore -id J01749 -format fasta |  transmute -cds2prot -circular -gcode 11 -all

will simultaneously translate three plus-strand and three minus-strand frames, including codons that span the origin if the molecule is circular:

  >J01749.1-1+  FSCLTAYHR*ALMR*FITVKLLTQSGTVYE ... KCHLTSKKPLLS*H*PIKIGVSRGPFVFKN  >J01749.1-2+  SHV*QLIIDKL*CGSLSQLNC*RSQAPCMK ... SAT*RLRNHYYHDINL*K*AYHEALSSSRI  >J01749.1-3+  LMFDSLSSISFNAVVYHS*IANAVRHRV*N ... VPPDV*ETIIIMTLTYKNRRITRPFRLQEF  >J01749.1-1-  ILEDERAS*YAYFYRLMS***WFLRRQVAL ... FIHGA*LR*QFNCDKLPH*SLSMISCQT*E  >J01749.1-2-  NS*RRKGLVIRLFL*VNVMIIMVS*TSGGT ... FHTRCLTALAI*L**TTALKLIDDKLSNMR  >J01749.1-3-  EFLKTKGPRDTPIFIG*CHDNNGFLDVRWH ... ISYTVPDCVSNLTVINYRIKAYR**AVKHE

### Pattern Searching

The pBR322 cloning vector is a circular plasmid with unique restriction sites in two antibiotic resistance genes.

The transmute -replace function introduces a second BamHI restriction enzyme recognition site by modifying two bases in the ribosomal binding site of the rop (restrictor of plasmid copy number) gene:

  efetch -db nuccore -id J01749 -format fasta |  transmute -replace -offset 1907 -delete GG -insert TC |

The transmute -search function takes a list of sequence patterns with optional labels (such as restriction enzyme names), and uses a finite-state algorithm to simultaneously search for all patterns:

  transmute -search -circular GGATCC:BamHI GAATTC:EcoRI CTGCAG:PstI |  align-columns -g 4 -a rl

The (0-based) starting positions and labels for each match are then printed in a two-column table:

   374    BamHI  1904    BamHI  3606    PstI  4358    EcoRI

The disambiguate-nucleotides and systematic-mutations scripts can generate all possible single-base substitutions in a pattern for a more relaxed search.

## Protein

### Amino Acid Composition

What is the amino acid composition of human titin?

  #!/bin/bash -norc  AAComp() {    abbrev=( Ala Asx Cys Asp Glu Phe Gly His Ile \             Xle Lys Leu Met Asn Pyl Pro Gln Arg \             Ser Thr Sec Val Trp Xxx Tyr Glx )    tr A-Z a-z |    sed 's/[^a-z]//g' |    fold -w 1 |    sort-uniq-count |    while read num lttr    do      idx=$(printf %i "'$lttr'")      ofs=$((idx-97))       echo -e "${abbrev[$ofs]}\t$num"    done |    sort  }  efetch -db protein -id Q8WZ42 -format gpc |  xtract -pattern INSDSeq -element INSDSeq_sequence |  AAComp

This produces a table of residue counts using the three-letter amino acid abbreviations:

  Ala    2084  Arg    1640  Asn    1111  Asp    1720  Cys    513  Gln    942  Glu    3193  Gly    2066  His    478  Ile    2062  Leu    2117  Lys    2943  Met    398  Phe    908  Pro    2517  Ser    2463  Thr    2546  Trp    466  Tyr    999  Val    3184

### Longest Sequences

What are the longest known insulin precursor molecules?

  esearch -db protein -query "insulin [PROT]" |  efetch -format docsum |  xtract -pattern DocumentSummary -element Caption Slen Title |  grep -v receptor | sort -k 2,2nr | head -n 5 | cut -f 1 |  xargs -n 1 sh -c 'efetch -db protein -id "$0" -format gp > "$0".gpf'

Post-processing excludes the longer "insulin-like receptor" sequences, sorts by sequence length, and saves the GenPept results to individual files named by their sequence accessions, using the right angle bracket (">") Unix output redirection character:

  EFN61235.gpf  EFN80340.gpf  EGW08477.gpf  EKC18433.gpf  ELK28555.gpf

### Archaea Enzyme

Which archaebacteria have chloramphenicol acetyltransferase?

  esearch -db protein -organism archaea \    -query "chloramphenicol acetyltransferase [PROT]" |  efetch -format gpc |  xtract -pattern INSDSeq -element INSDSeq_organism INSDSeq_definition |  grep -i chloramphenicol | grep -v MULTISPECIES |  cut -f 1 | sort -f | uniq -i

Filtering on the definition line produces a list of archaeal organism names:

  Euryarchaeota archaeon  Methanobrevibacter arboriphilus  Methanobrevibacter gottschalkii  Methanobrevibacter millerae  Methanobrevibacter oralis  ...

## Gene

### Gene Counts

How many genes are on each human chromosome?

  for chr in {1..22} X Y MT  do    esearch -db gene -query "Homo sapiens [ORGN] AND $chr [CHR]" |    efilter -status alive -type coding |    efetch -format docsum |    xtract -pattern DocumentSummary -NAME Name \      -block GenomicInfoType -if ChrLoc -equals "$chr" \        -tab "\n" -element ChrLoc,"&NAME" |    sort | uniq | cut -f 1 |    sort-uniq-count-rank |    reorder-columns 2 1  done

This returns a count of unique protein-coding genes per chromosome:

  1     2011  2     1224  3     1046  4     742  5     854  6     1015  7     911  8     666  9     763  10    718  11    1279  12    1012  13    327  14    601  15    585  16    835  17    1147  18    266  19    1391  20    528  21    232  22    429  X     839  Y     63  MT    13

The range construct cannot be used for Roman numerals, so the equivalent query on Saccharomyces cerevisiae would need to explicitly list all chromosomes, including the mitochondrion:

  for chr in I II III IV V VI VII VIII IX X XI XII XIII XIV XV XVI MT

Plastid genes can be selected with "source plastid [PROP]" or ‑location plastid.

### Chromosome Locations

Where are mammalian calmodulin genes located?

  esearch -db gene -query "calmodulin * [PFN] AND mammalia [ORGN]" |  efetch -format docsum |  xtract -pattern DocumentSummary \    -def "-" -element Id Name MapLocation ScientificName

The ‑def command adds a dash to prevent missing data from shifting columns in the table:

  801       CALM1     14q32.11     Homo sapiens  808       CALM3     19q13.32     Homo sapiens  805       CALM2     2p21         Homo sapiens  24242     Calm1     6q32         Rattus norvegicus  12313     Calm1     12 E         Mus musculus  50663     Calm2     6q12         Rattus norvegicus  24244     Calm3     1q21         Rattus norvegicus  12315     Calm3     7 9.15 cM    Mus musculus  12314     Calm2     17 E4        Mus musculus  80796     Calm4     13 A1        Mus musculus  617095    CALM1     -            Bos taurus  396838    CALM3     -            Sus scrofa  520277    CALM3     -            Bos taurus  364774    Calml5    17q12.2      Rattus norvegicus  ...

### Exon Counts

How many exons are in each dystrophin transcript variant?

  esearch -db gene -query "DMD [GENE] AND human [ORGN]" |  efetch -format docsum |  xtract -pattern DocumentSummary -block GenomicInfoType \    -tab "\n" -element ChrAccVer,ChrStart,ChrStop |  xargs -n 3 sh -c 'efetch -db nuccore -format gbc \    -id "$0" -chr_start "$1" -chr_stop "$2"' |

This retrieves an INSDSeq XML subset record for the indicated gene region, which contains a number of alternatively-spliced dystrophin mRNA and CDS features.

Data extraction computes the number of intervals for each mRNA location (individual exons plus non-adjacent UTRs), and obtains the transcript sequence accession, transcript length, and product name from qualifiers:

  xtract -insd complete mRNA "#INSDInterval" \    transcript_id "%transcription" product |

Final filtering and sorting:

  grep -i dystrophin |  sed 's/dystrophin, transcript variant //g' |  sort -k 2,2nr -k 4,4nr

results in a table of exon counts and transcript lengths:

  NC_000023.11    79    NM_004010.3       14083    Dp427p2  NC_000023.11    79    NM_004009.3       14000    Dp427p1  NC_000023.11    79    NM_004006.3       13992    Dp427m  NC_000023.11    79    NM_000109.4       13854    Dp427c  NC_000023.11    78    XM_006724468.2    13923    X1  NC_000023.11    78    XM_017029328.1    13916    X4  NC_000023.11    78    XM_006724469.3    13897    X2  NC_000023.11    77    XM_006724470.3    13875    X3  ...

### Upstream Sequences

What sequences are upstream of phenylalanine hydroxylase genes?

  esearch -db nuccore -query "U49897 [ACCN]" |  elink -target gene |  elink -target homologene |  elink -target gene |  efetch -format docsum |  xtract -pattern DocumentSummary -if GenomicInfoType -element Id \    -block GenomicInfoType -element ChrAccVer -1-based ChrStart ChrStop |

This produces a table with 1-based sequence coordinates:

  5053       NC_000012.12    102958441    102836889  18478      NC_000076.7     87357657     87419999  38871      NT_037436.4     7760453      7763166  24616      NC_005106.4     28066639     28129772  378962     NC_007115.7     17409367     17391680  ...

Then, given a shell script named "upstream.sh":

  #!/bin/bash -norc  bases=1500  if [ -n "$1" ]  then    bases="$1"  fi  while read id accn start stop  do    if [ $start -eq 0 ] || [ $stop -eq 0 ] || [ $start -eq $stop ]    then      echo "Skipping $id due to ambiguous coordinates"      continue    fi    if [ $start -gt $stop ]    then      stop=$(( start + bases ))      start=$(( start + 1 ))      strand=2    else      stop=$(( start - 1 ))      start=$(( start - bases ))      strand=1    fi    rslt=$( efetch -db nuccore -id $accn -format fasta \            -seq_start $start -seq_stop $stop -strand $strand < /dev/null )    echo "$rslt"  done

the data lines can be piped through:

  upstream.sh 500

to extract and print the 500 nucleotides immediately upstream of each gene:

  >NC_000012.12:c102958941-102958442 Homo sapiens chromosome 12, GRCh38.p13 ...  TGAAGTCGAGAAGCTCCTGCTCCTCGGGGCTGAGCGGGTCGTAAGAGCCCTCGTCCGACGAGTAGGATGA  GACCGGCGAGCCGGCCATGGAGTTCAAGTCGTTGGAGTAGTTGGGGGAGATGGTGGGCGACAGGACGCCT  GCCTGGAAGGCGGCGCTCACCGCGTCATGCTCGTCCAGCAGCTGCTGCAGCGCGCGGATGTACTCGACCG  ...

### Interactions Table

What genes interact with human epidermal growth factor receptor?

The Interactions table for the human EGFR (epidermal growth factor receptor) gene at:

  https://www.ncbi.nlm.nih.gov/gene/?term=1956#interactions

can be reconstructed as a tab-delimited table without hyperlinks using fresh data and a processing chain of xtract commands. After downloading the gene record in XML format:

  efetch -db gene -id 1956 -format xml |

the first xtract command isolates the "Interactions" section and saves its components as individual entries:

  xtract -set Set -pattern Entrezgene \    -wrp GENEID -GENEID Gene-track_geneid -wrp SYMBOL -SYMBOL Gene-ref_locus \    -division Entrezgene_comments \      -group Gene-commentary -if Gene-commentary_heading -equals Interactions \        -branch "*/Gene-commentary" -pkg Rec -element "&GENEID" "&SYMBOL" \          -block "Gene-commentary/*" -element "*" |

These are piped to a second xtract command that collects and reformats the source reference objects:

  xtract -transform <( echo -e "1\tSOURCE\n2\tPRODUCT\n3\tOTHERGENE\n4\tINTERACT\n" ) \    -rec Rec -pattern Rec -if "#Other-source" -eq 4 \      -wrp DESCR -element Gene-commentary_text -wrp PMIDS -sep "|" -element PubMedId \      -group GENEID -element "*" \      -group SYMBOL -element "*" \      -group Other-source -PS "+" -DB "" -ID "" -AC "" \        -DB Dbtag_db -ID -first "Object-id_str,Object-id_id" -AC Other-source_anchor \        -branch Other-source -DBID "" -ACDBID "" \          -block Other-source -if "&DB" -and "&ID" \            -sep ":" -DBID "&DB,&ID" \          -block Other-source -if "&AC" -and "&DBID" \            -sep " [" -sfx "]" -ACDBID "&AC,&DBID"\          -block Other-source \            -pfx "<" -sfx ">" -translate "&PS" -rst \            -first "&ACDBID,&AC,&DBID" \            -pfx "</" -sfx ">" -translate "&PS" |

storing them in XML objects that use the name of the column:

  ...  <Rec>    <DESCR>EGFR interacts with calmodulin</DESCR>    <PMIDS>14960328</PMIDS>    <GENEID>1956</GENEID>    <SYMBOL>EGFR</SYMBOL>    <SOURCE>BIND [BIND:58062]</SOURCE>    <PRODUCT>NP_005219.2 [Protein:29725609]</PRODUCT>    <OTHERGENE>CALM1 [GeneID:801]</OTHERGENE>    <INTERACT>NP_008819.1 [Protein:5901912]</INTERACT>  </Rec>  ...

This is passed to a final xtract command that prints the fields in the desired order:

  xtract -pattern Rec -def "-" \    -element GENEID SYMBOL PRODUCT INTERACT OTHERGENE COMPLEX SOURCE PMIDS DESCR

## Assembly

### Complete Genomes

What complete genomes are available for Escherichia coli?

  esearch -db assembly -query \    "Escherichia coli [ORGN] AND representative [PROP]" |  elink -target nuccore -name assembly_nuccore_refseq |  efetch -format docsum |  xtract -pattern DocumentSummary -element AccessionVersion Slen Title |  sed 's/,.*//' |  sort-table -k 2,2nr

This search finds genomic assemblies and sorts the results by sequence length, allowing complete genomes to be easily distinguished from smaller plasmids:

  NC_002695.2    5498578    Escherichia coli O157:H7 str. Sakai DNA  NC_000913.3    4641652    Escherichia coli str. K-12 substr. MG1655  NC_002128.1    92721      Escherichia coli O157:H7 str. Sakai plasmid pO157  NC_002127.1    3306       Escherichia coli O157:H7 str. Sakai plasmid pOSAK1

The sed command removes text (e.g., complete genome, complete sequence, primary assembly) after a comma.

A similar query for humans, additionally filtering out scaffolds, contigs, and plasmids:

  esearch -db assembly -query "Homo sapiens [ORGN] AND representative [PROP]" |  elink -target nuccore -name assembly_nuccore_refseq |  efetch -format docsum |  xtract -pattern DocumentSummary -element AccessionVersion Slen Title |  sed 's/,.*//' |  grep -v scaffold | grep -v contig | grep -v plasmid | grep -v patch |  sort

returns the assembled chromosome and mitochondrial sequence records:

  NC_000001.11    248956422    Homo sapiens chromosome 1  NC_000002.12    242193529    Homo sapiens chromosome 2  NC_000003.12    198295559    Homo sapiens chromosome 3  NC_000004.12    190214555    Homo sapiens chromosome 4  NC_000005.10    181538259    Homo sapiens chromosome 5  NC_000006.12    170805979    Homo sapiens chromosome 6  NC_000007.14    159345973    Homo sapiens chromosome 7  NC_000008.11    145138636    Homo sapiens chromosome 8  NC_000009.12    138394717    Homo sapiens chromosome 9  NC_000010.11    133797422    Homo sapiens chromosome 10  NC_000011.10    135086622    Homo sapiens chromosome 11  NC_000012.12    133275309    Homo sapiens chromosome 12  NC_000013.11    114364328    Homo sapiens chromosome 13  NC_000014.9     107043718    Homo sapiens chromosome 14  NC_000015.10    101991189    Homo sapiens chromosome 15  NC_000016.10    90338345     Homo sapiens chromosome 16  NC_000017.11    83257441     Homo sapiens chromosome 17  NC_000018.10    80373285     Homo sapiens chromosome 18  NC_000019.10    58617616     Homo sapiens chromosome 19  NC_000020.11    64444167     Homo sapiens chromosome 20  NC_000021.9     46709983     Homo sapiens chromosome 21  NC_000022.11    50818468     Homo sapiens chromosome 22  NC_000023.11    156040895    Homo sapiens chromosome X  NC_000024.10    57227415     Homo sapiens chromosome Y  NC_012920.1     16569        Homo sapiens mitochondrion

This process can be automated to loop through a list of specified organisms:

  for org in \    "Agrobacterium tumefaciens" \    "Bacillus anthracis" \    "Escherichia coli" \    "Neisseria gonorrhoeae" \    "Pseudomonas aeruginosa" \    "Shigella flexneri" \    "Streptococcus pneumoniae"  do    esearch -db assembly -query "$org [ORGN]" |    efilter -query "representative [PROP]" |    elink -target nuccore -name assembly_nuccore_refseq |    efetch -format docsum |    xtract -pattern DocumentSummary -element AccessionVersion Slen Title |    sed 's/,.*//' |    grep -v -i -e scaffold -e contig -e plasmid -e sequence -e patch |    sort-table -k 2,2nr  done

which generates:

  NC_011985.1    4005130    Agrobacterium radiobacter K84 chromosome 1  NC_011983.1    2650913    Agrobacterium radiobacter K84 chromosome 2  NC_005945.1    5228663    Bacillus anthracis str. Sterne chromosome  NC_003997.3    5227293    Bacillus anthracis str. Ames chromosome  NC_002695.1    5498450    Escherichia coli O157:H7 str. Sakai chromosome  NC_018658.1    5273097    Escherichia coli O104:H4 str. 2011C-3493 ...  NC_011751.1    5202090    Escherichia coli UMN026 chromosome  NC_011750.1    5132068    Escherichia coli IAI39 chromosome  NC_017634.1    4747819    Escherichia coli O83:H1 str. NRG 857C chromosome  NC_000913.3    4641652    Escherichia coli str. K-12 substr. MG1655  NC_002946.2    2153922    Neisseria gonorrhoeae FA 1090 chromosome  NC_002516.2    6264404    Pseudomonas aeruginosa PAO1 chromosome  NC_004337.2    4607202    Shigella flexneri 2a str. 301 chromosome  NC_003028.3    2160842    Streptococcus pneumoniae TIGR4 chromosome  NC_003098.1    2038615    Streptococcus pneumoniae R6 chromosome

## SNP

### SNP Data Table

How can you obtain a tab-delimited table of SNP attributes from a document summary?

  efetch -db snp -id 11549407 -format docsum |  snp2tbl

The snp2tbl script extracts fields from HGVS data and prints the individual values for further processing:

  rs11549407    NC_000011.10    5226773    G    A    Genomic    Substitution    HBB  rs11549407    NC_000011.10    5226773    G    C    Genomic    Substitution    HBB  rs11549407    NC_000011.10    5226773    G    T    Genomic    Substitution    HBB  rs11549407    NG_000007.3     70841      C    A    Genomic    Substitution    HBB  rs11549407    NG_000007.3     70841      C    G    Genomic    Substitution    HBB  rs11549407    NG_000007.3     70841      C    T    Genomic    Substitution    HBB  ...   rs11549407    NM_000518.5     167        C    A    Coding     Substitution    HBB  rs11549407    NM_000518.5     167        C    G    Coding     Substitution    HBB  rs11549407    NM_000518.5     167        C    T    Coding     Substitution    HBB  rs11549407    NP_000509.1     39         Q    *    Protein    Termination     HBB  rs11549407    NP_000509.1     39         Q    E    Protein    Missense        HBB  rs11549407    NP_000509.1     39         Q    K    Protein    Missense        HBB

Columns are SNP identifier, accession.version, offset from start of sequence, letters to delete, letters to insert, sequence class, variant type, and gene name. The internal steps (snp2hgvs, hgvs2spdi, and spdi2tbl) are described below.

### Amino Acid Substitutions

What are the missense products of green-sensitive opsin?

  esearch -db gene -query "OPN1MW [PREF] AND human [ORGN]" |  elink -target snp | efilter -class missense |  efetch -format docsum |

SNP document summaries contain HGVS data of the form:

  NC_000023.11:g.154193517C>A, ... ,NP_000504.1:p.Ala285Val

This can be parsed by an xtract ‑hgvs command within the snp2hgvs script:

  snp2hgvs |

into a structured representation of nucleotide and amino acid replacements:

  ...  <HGVS>    <Id>782327292</Id>    <Gene>OPN1MW</Gene>    <Variant>      <Class>Genomic</Class>      <Type>Substitution</Type>      <Accession>NC_000023.11</Accession>      <Position>154193516</Position>      <Deleted>C</Deleted>      <Inserted>A</Inserted>      <Hgvs>NC_000023.11:g.154193517C&gt;A</Hgvs>    </Variant>    ...    <Variant>      <Class>Coding</Class>      <Type>Substitution</Type>      <Accession>NM_000513.2</Accession>      <Offset>853</Offset>      <Deleted>C</Deleted>      <Inserted>T</Inserted>      <Hgvs>NM_000513.2:c.854C&gt;T</Hgvs>    </Variant>    <Variant>      <Class>Protein</Class>      <Type>Missense</Type>      <Accession>NP_000504.1</Accession>      <Position>284</Position>      <Deleted>A</Deleted>      <Inserted>D</Inserted>      <Hgvs>NP_000504.1:p.Ala285Asp</Hgvs>    </Variant>    <Variant>      <Class>Protein</Class>      <Type>Missense</Type>      <Accession>NP_000504.1</Accession>      <Position>284</Position>      <Deleted>A</Deleted>      <Inserted>V</Inserted>      <Hgvs>NP_000504.1:p.Ala285Val</Hgvs>    </Variant>  </HGVS>  ...

where the original 1-based HGVS positions are converted to 0-based in the XML.

Passing those results through the hgvs2spdi script:

  hgvs2spdi |

converts CDS-relative offsets to sequence-relative positions:

  ...  <SPDI>    <Id>782327292</Id>    <Gene>OPN1MW</Gene>    ...    <Variant>      <Class>Coding</Class>      <Type>Substitution</Type>      <Accession>NM_000513.2</Accession>      <Position>935</Position>      <Offset>853</Offset>      <Deleted>C</Deleted>      <Inserted>A</Inserted>      <Hgvs>NM_000513.2:c.854C&gt;A</Hgvs>      <Spdi>NM_000513.2:935:C:A</Spdi>    </Variant>    <Variant>      <Class>Coding</Class>      <Type>Substitution</Type>      <Accession>NM_000513.2</Accession>      <Position>935</Position>      <Offset>853</Offset>      <Deleted>C</Deleted>      <Inserted>T</Inserted>      <Hgvs>NM_000513.2:c.854C&gt;T</Hgvs>      <Spdi>NM_000513.2:935:C:T</Spdi>    </Variant>    ...  </SPDI>  ...

Piping this through the spdi2tbl script:

  spdi2tbl |

completes the final step of the snp2tbl process to generate a SNP Data Table. Filtering that through:

  grep Protein | grep Missense | cut -f 1-5

results in a table of amino acid substitutions sorted by accession, position, and residue:

  rs1238141906    NP_000504.1    40    E    K  rs1189783086    NP_000504.1    42    P    L  rs1257135801    NP_000504.1    45    H    Y  rs1284438666    NP_000504.1    63    V    I  rs1223726997    NP_000504.1    64    I    T  ...

Those rows are processed in a while loop that caches the current sequence data:

  while read rsid accn ofs del ins  do    if [ "$accn" != "$last" ]    then      seq=$( efetch -db protein -id "$accn" -format gpc < /dev/null |             xtract -pattern INSDSeq -lower INSDSeq_sequence )      last="$accn"    fi    pos=$((ofs + 1))    echo ">$rsid [$accn $ins@$pos]"    echo "$seq" |    transmute -replace -offset "$ofs" -delete "$del" -insert "$ins" -lower |    fold -w 50  done

and uses transmute ‑replace to generate modified FASTA with substituted residues in upper case:

  >rs1238141906 [NP_000504.1 K@41]  maqqwslqrlagrhpqdsyedstqssiftytnsnstrgpfKgpnyhiapr  wvyhltsvwmifvviasvftnglvlaatmkfkklrhplnwilvnlavadl  aetviastisvvnqvygyfvlghpmcvlegytvslcgitglwslaiiswe  ...

### SNP-Modified Product Pairs

How can you match codon modifications with amino acid substitutions?

  efetch -db snp -id 11549407 -format docsum |  snp2tbl |  tbl2prod

For SNPs that have different substitutions at the same position, the tbl2prod script translates coding sequences (after nucleotide modification), and sorts them with protein sequences (after residue replacement), to produce adjacent matching CDS/protein pairs:

  rs11549407    NM_000518.5:167:C:T    MVHLTPEEKSAVTALWGKVNVDEVGGEALGRLLVVYPWT*R...  rs11549407    NP_000509.1:39:Q:*     MVHLTPEEKSAVTALWGKVNVDEVGGEALGRLLVVYPWT*R...  rs11549407    NM_000518.5:167:C:G    MVHLTPEEKSAVTALWGKVNVDEVGGEALGRLLVVYPWTER...  rs11549407    NP_000509.1:39:Q:E     MVHLTPEEKSAVTALWGKVNVDEVGGEALGRLLVVYPWTER...  rs11549407    NM_000518.5:167:C:A    MVHLTPEEKSAVTALWGKVNVDEVGGEALGRLLVVYPWTKR...  rs11549407    NP_000509.1:39:Q:K     MVHLTPEEKSAVTALWGKVNVDEVGGEALGRLLVVYPWTKR...  rs11549407    NM_000518.5:167:C:+    MVHLTPEEKSAVTALWGKVNVDEVGGEALGRLLVVYPWTQR...  rs11549407    NP_000509.1:39:Q:+     MVHLTPEEKSAVTALWGKVNVDEVGGEALGRLLVVYPWTQR...

The "+" sign indicates the unmodified "wild-type" nucleotide or amino acid.

## Structure

### Structural Similarity

What archaea structures are similar to snake venom phospholipase?

  esearch -db structure -query "crotalus [ORGN] AND phospholipase A2" |  elink -related |  efilter -query "archaea [ORGN]" |  efetch -format docsum |  xtract -pattern DocumentSummary \    -if PdbClass -equals Hydrolase \      -element PdbDescr |  sort -f | uniq -i

Structure neighbors use geometric comparison to find proteins that are too divergent to be detected by sequence similarity with a BLAST search:

  Crystal Structure Of Autoprocessed Form Of Tk-Subtilisin  Crystal Structure Of Ca2 Site Mutant Of Pro-S324a  Crystal Structure Of Ca3 Site Mutant Of Pro-S324a  ...

## Taxonomy

### Taxonomic Lineage

What are the major taxonomic lineage nodes for humans?

  efetch -db taxonomy -id 9606 -format xml |  xtract -pattern Taxon -first TaxId -tab "\n" -element ScientificName \    -block "**/Taxon" \      -if Rank -is-not "no rank" -and Rank -is-not clade \        -tab "\n" -element Rank,ScientificName

This uses the double star / child construct to recursively explore the data hierarchy:

  9606            Homo sapiens  superkingdom    Eukaryota  kingdom         Metazoa  phylum          Chordata  subphylum       Craniata  superclass      Sarcopterygii  class           Mammalia  superorder      Euarchontoglires  order           Primates  ...

### Taxonomy Search

Which organisms contain an annotated RefSeq genome MatK gene?

  esearch -db nuccore -query "MatK [GENE] AND NC_0:NC_999999999 [PACC]" |  efetch -format docsum |  xtract -pattern DocumentSummary -element TaxId |  sort -n | uniq |  epost -db taxonomy |  efetch -format docsum |  xtract -pattern DocumentSummary -element ScientificName |  sort

The first query obtains taxonomy UIDs from nucleotide document summaries and uploads them for separate retrieval from the taxonomy database:

  Acidosasa purpurea  Acorus americanus  ...  Zingiber spectabile  Zygnema circumcarinatum

## BioSample

BioSample document summaries:

  esummary -db biosample -id SAMN34375013 |

use XML attributes to identify data element types:

  <Attribute attribute_name="strain" harmonized_name="strain" ...>KF24</Attribute>

A two-stage xtract pipeline can produce a tab-delimited table, with one column for each selected field. Piping the data to the first command:

  xtract -rec BioSampleInfo -pattern DocumentSummary \    -wrp Accession -element Accession \    -wrp Title -element DocumentSummary/Title \    -wrp Link -sep "|" -numeric Links/Link \    -group Attribute -if @harmonized_name \      -TAG -lower @harmonized_name -wrp "&TAG" -element Attribute |

generates an intermediate form, with XML object names taken from the "harmonized_name" attributes:

  <BioSampleInfo>    <Accession>SAMN34375013</Accession>    <Title>Microbe sample from Bacillus subtilis</Title>    <Link>960711</Link>    <isolation_source>rhizosphere soil</isolation_source>    <collection_date>missing</collection_date>    <geo_loc_name>China: Kaifeng, Henan Province</geo_loc_name>    <sample_type>bacterial isolate</sample_type>    <lat_lon>34.14 N 114.05 E</lat_lon>    <strain>KF24</strain>  </BioSampleInfo>

(A bsmp2info script containing this first xtract command is now included with EDirect.)

Desired fields can then be selected by name in the last line of the second xtract command, with a "-" placeholder printed for any missing values:

  xtract -pattern BioSampleInfo -def "-" -first Accession Title Link \    geo_loc_name isolation_source strain lat_lon

Using ‑first instead of ‑element eliminates possible redundant entries during the attribute name transition from "country" to "geo_loc_name".

## SRA

### Using RunInfo Format

SRA data can be retrieved in RunInfo format:

  efetch -db sra -id SRR6314034 -format runinfo |

as comma-separated values, with the first line containing the field names:

  Run,ReleaseDate,LoadDate,spots,bases,spots_with_mates,avgLength,...  SRR6314034,2017-11-21 23:27:11,2017-11-21 23:25:38,128,539118,0,...

Piping to the csv2xml script, and using the ‑header flag:

  csv2xml -set Set -rec Rec -header |

converts the data into XML:

  <Set>    <Rec>      <Run>SRR6314034</Run>      <ReleaseDate>2017-11-21 23:27:11</ReleaseDate>      <LoadDate>2017-11-21 23:25:38</LoadDate>      <spots>128</spots>      <bases>539118</bases>      <spots_with_mates>0</spots_with_mates>      <avgLength>4211</avgLength>      <size_MB>0</size_MB>      <AssemblyName></AssemblyName>      <download_path>...</download_path>      <Experiment>SRX3413965</Experiment>      <LibraryName>child</LibraryName>      <LibraryStrategy>AMPLICON</LibraryStrategy>      <LibrarySelection>PCR</LibrarySelection>      <LibrarySource>GENOMIC</LibrarySource>      <LibraryLayout>SINGLE</LibraryLayout>      <InsertSize>0</InsertSize>      <InsertDev>0</InsertDev>      <Platform>PACBIO_SMRT</Platform>      <Model>PacBio RS II</Model>      <SRAStudy>SRP125431</SRAStudy>      <BioProject>PRJNA418990</BioProject>      <Study_Pubmed_id></Study_Pubmed_id>      <ProjectID>418990</ProjectID>      <Sample>SRS2707133</Sample>      <BioSample>SAMN08040264</BioSample>      <SampleType>simple</SampleType>      <TaxID>9606</TaxID>      <ScientificName>Homo sapiens</ScientificName>      <SampleName>BBS9_del_mother</SampleName>      <g1k_pop_code></g1k_pop_code>      <source></source>      <g1k_analysis_group></g1k_analysis_group>      <Subject_ID></Subject_ID>      <Sex>female</Sex>      <Disease></Disease>      <Tumor>no</Tumor>      <Affection_Status></Affection_Status>      <Analyte_Type></Analyte_Type>      <Histological_Type></Histological_Type>      <Body_Site></Body_Site>      <CenterName>ICAHN SCHOOL OF MEDICINE AT MOUNT SINAI</CenterName>      <Submission>SRA633054</Submission>      <dbgap_study_accession></dbgap_study_accession>      <Consent>public</Consent>      <RunHash>19AC4EB8A65D733274756464DCCF65EA</RunHash>      <ReadHash>AC8F39C51F95D9CD1BD0CBFBB669AD1E</ReadHash>    </Rec>  </Set>

This can then be piped through xtract:

  xtract -pattern Rec -def "-" -element Run Experiment BioProject BioSample

to retrieve the desired values by field name:

  SRR6314034    SRX3413965    PRJNA418990    SAMN08040264

### Installation of EDirect on the Cloud

To install the EDirect software, open a terminal window and execute the following command:

  sh -c "$(curl -fsSL https://ftp.ncbi.nlm.nih.gov/entrez/entrezdirect/install-edirect.sh)"

At the end of installation, answer "y" to have the script run the PATH update command to edit your configuration file, so that EDirect programs can be run in subsequent terminal sessions.

One installation is complete, run:

  export PATH=${PATH}:${HOME}/edirect

to set the PATH for the current terminal session.

### Downloading BLAST Software

Obtain the Magic-BLAST software if it is not already installed:

  download-ncbi-software magic-blast

### Preparing Chromosome Files

Retrieve the sequence of human chromosome 7 with:

  efetch -db nuccore -id NC_000007 -format fasta -immediate > NC_000007.fsa

Download protein-coding genes on human chromosome 7 in document summary format, and extract the gene ranges into a tab-delimited table:

  esearch -db gene -query "Homo sapiens [ORGN] AND 7 [CHR]" |  efilter -status alive -type coding | efetch -format docsum |  gene2range "7" > NC_000007.gen

### SRA Gene Analysis

Run a magicblast search of SRR6314034 against chromosome 7:

  magicblast -sra SRR6314034 -subject NC_000007.fsa -outfmt asn |  asn2xml > SRR6314034.xml

Passing the alignment details through the blst2tkns script:

  cat SRR6314034.xml |  blst2tkns |

tokenizes the alignment parts:

  index          1  score          6268  start          33088037  stop           33167397  strand         plus  match          12  mismatch       1  genomic-ins    1  ...

Piping these to the split-at-intron script:

  split-at-intron |

detects large genomic insertions:

  6268    1    plus    33088037..33091003,33163798..33167397  4910    2    plus    33089462..33091003,33163799..33167397  1814    3    plus    33164965..33167397  ...

These are filtered by minimum score with:

  filter-columns '$1 > 1000' |

The fuse-ranges script then merges overlapping alignments:

  fuse-ranges |

into a minimal set of extended ranges:

  plus     33088037    33091003    2967  plus     33163798    33167398    3601  plus     33272248    33272278    31  plus     33394238    33394551    314  minus    33088037    33091004    2968  minus    33163798    33167398    3601  minus    33255886    33256012    127  minus    33394326    33394551    226

Running each range through the find-in-gene script:

  while read std min max len  do    cat NC_000007.gen |    find-in-gene "$std" "$min" "$max"  done |  sort -f | uniq -i

returns the names of gene(s) that overlap the aligned segments:

  BBS9

## PubChem

### PubChem in Entrez

Entrez can search on the complete synonym of a compound:

  esearch -db pccompound -query "catechol [CSYN]" |  efetch -format uid

to return a small number of closely matching compound identifiers (CIDs):

  73160  9064  289

Entrez document summaries for a compound:

  efetch -db pccompound -id 289 -format docsum |  xtract -pattern DocumentSummary -element MolecularFormula IsomericSmiles

contains general descriptive information fields for the compound:

  C6H6O2    C1=CC=C(C(=C1)O)O

### Power User Gateway (PUG) REST Query Form

PubChem also supports a RESTful service for more advanced queries. Nquire provides a ‑pugrest URL shortcut. The base form of a search request is is:

  nquire -pugrest [compound|substance|assay] [input] [operation] [output]

Searches can use the name of a compound:

  nquire -pugrest compound name catechol cids TXT

to obtain the best matching compound identifier:

  289

The CID can be used as the input key to obtain a title and description:

  nquire -pugrest compound cid 289 description XML

or to retrieve a much more detailed record:

  nquire -pugrest compound cid 289 record XML |

that includes the canonical or isomeric SMILES codes:

  xtract -pattern PC-InfoData \    -if PC-Urn_label -equals SMILES -and PC-Urn_name -equals Isomeric \      -element PC-InfoData_value_sval

### PubChem Chemical Identifiers

Certain identifier types require POST arguments to encode special symbols:

  nquire -pugrest compound smiles description XML \    -smiles "C1=CC=C(C(=C1)O)O" |  xtract -pattern InformationList -element Title Description

This returns the chemical name and description:

  Catechol    Catechol is a benzenediol comprising...

Other identifier key types that are encoded in separate arguments are shown below:

  nquire -pugrest compound inchi synonyms TXT \    -inchi "1S/C6H6O2/c7-5-3-1-2-4-6(5)8/h1-4,7-8H"  nquire -pugrest compound inchikey cids JSON \    -inchikey "YCIMNLLNPGFGHC-UHFFFAOYSA-N"  nquire -pugrest compound/fastsubstructure/smarts/cids/XML \    -smarts "[#7]-[#6]-1=[#6]-[#6](C#C)=[#6](-[#6]-[#8])-[#6]=[#6]-1"

(Nquire ‑inchi will supply the expected "InChI=" prefix if it is missing in the argument string.)

### PUG-REST Asynchronous Queries

Some PUG-REST queries are computationally intensive and run asynchronously:

  nquire -pugrest compound/superstructure/cid/2244/XML |

The returned <ListKey> token is piped to an nquire ‑pugwait command, which polls the server until the results are available:

  nquire -pugwait

Identifiers are then downloaded and placed directly in an ENTREZ_DIRECT message:

  <ENTREZ_DIRECT>    <Db>pccompound</Db>    <Count>3750</Count>    <Id>87</Id>    <Id>175</Id>    <Id>176</Id>    ...    <Id>162400221</Id>    <Id>162416056</Id>    <Id>162417911</Id>  </ENTREZ_DIRECT>

Support for this form was added when EDirect was redesigned in 2020.

## Bibliometrics

### Reverse Chronological Order

Repackaging an entire document summary and creating a set of keys for sorting:

  esearch -db pubmed -query "tn3 transposition immunity" |  efetch -format docsum |  xtract -rec Rec -pattern DocumentSummary -INDX "+" \    -group DocumentSummary -pkg SortKeys \      -unit DocumentSummary -wrp INDX -element "&INDX" \      -unit PubDate -wrp YEAR -year PubDate \      -unit PubDate -wrp DATE -date "*" \      -unit Title -wrp TITL -lower Title \      -unit Author -position first -wrp FAUT -lower Name \      -unit Author -position last -wrp LAUT -lower Name \      -unit Authors -wrp ANUM -num Author/Name \      -unit DocumentSummary -wrp SIZE -len "*" \    -group DocumentSummary -pkg DS -element "*" |

produces an intermediate structure with separate containers for the sort keys and the original docsum:

  ...  <Rec>    <SortKeys>      <INDX>5</INDX>      <YEAR>1989</YEAR>      <DATE>1989/04</DATE>      <TITL>nucleotide sequences required for tn3 transposition immunity.</TITL>      <FAUT>kans ja</FAUT>      <LAUT>casadaban mj</LAUT>      <ANUM>2</ANUM>      <SIZE>1695</SIZE>    </SortKeys>    <DS>      <DocumentSummary>        <Id>2539356</Id>        <PubDate>1989 Apr</PubDate>        <Source>J Bacteriol</Source>        ...      </DocumentSummary>    </DS>  </Rec>  ...

This allows sorting of records by a new tag derived from ‑year:

  xtract -rec Rec -pattern Rec -sort-rev SortKeys/YEAR |  xtract -set DocumentSummarySet -pattern Rec \    -group DS/DocumentSummary -element "*" |  transmute -format -combine |  xtract -pattern DocumentSummary -element Id PubDate

to present publication records with the most recent shown first:

  36257990    2022 Oct 18  28096365    2017 Jan 31  22624153    2012 Feb  21729108    2011 Sep  8595595     1996 Jan

### Count Unique Journals

Some bibliometric analyses require fetching huge numbers of PubMed records. One such example is counting the number of unique journals publishing papers indexed under a given category.

A common function consolidates code to execute a query and fetch the records from the EDirect local PubMed archive. The xtract ‑histogram shortcut acts as an ‑element command followed by a built-in sort-uniq-count. (This can save significant time when the number of results is in the millions.) The line count gives the number of journals publishing at least one paper that satisfies the query:

  CountUniqueJournals() {    qry="$1"    # count number of unique journals publishing papers that match a query    phrase-search -db pubmed -query "$qry" | fetch-pubmed |    xtract -pattern PubmedArticle -histogram Journal/ISOAbbreviation |    wc -l | tr -d ' '  }

Looping through a series of years, and calling this function with and without a filter of interest in the query:

  for year in {2016..2022}  do    # want to find percent of journals still using unstructured date    filt="medline date [PROP]"     base="journal article [PTYP] AND $year [YEAR]"     # subset of journals publishing a paper with filter condition    subs=$( CountUniqueJournals "$base AND $filt" )     # number of unique journals in selected publication types    totl=$( CountUniqueJournals "$base" )     frac="-"    if [ "$totl" -gt 0 ]     then      # calculate (integer) percentage      frac=$((subs * 100 / totl))     fi    # print year, journal counts, and percent using filter condition    printf "$year\t$subs\t$totl\t$frac\n"  done | align-columns -h 2 -g 4 -a r

returns the year, the numbers of unique journals with the filter and in total for that year, and the ratio of the two as a percentage. In this example the last column shows a steady decrease in the percentage of journals providing an unstructured publication date:

  2016    1933    10362    18  2017    1153    10473    11  2018    1071    10321    10  2019     980    10027     9  2020     919    10579     8  2021     950    10947     8  2022     835    10600     7