# The E-utility Web Service (SOAP)

## Termination Announcement

The SOAP web service for the E-utilities will be TERMINATED permanently on July 1, 2015. All requests made to this service after that date will fail.

If you have software that is currently using the E-utility SOAP web service, please plan to transition to using the standard URL interface described in Chapters 1-4 of this book.

Please contact info@ncbi.nlm.nih.gov if you have questions about this change.

## For More Information

E-utility DTDs

Please see Chapter 1 for getting additional information about the E-utilities.