# The E-utilities In-Depth: Parameters, Syntax and More

## Introduction

This chapter serves as a reference for all supported parameters for the E-utilities, along with accepted values and usage guidelines. This information is provided for each E-utility in sections below, and parameters and/or values specific to particular databases are discussed within each section. Most E-utilities have a set of parameters that are required for any call, in addition to several additional optional parameters that extend the tool's functionality. These two sets of parameters are discussed separately in each section.

## General Usage Guidelines

Please see Chapter 2 for a detailed discussion of E-utility usage policy. The following two parameters should be included in all E-utility requests.

### tool

Name of application making the E-utility call. Value must be a string with no internal spaces.

### email

E-mail address of the E-utility user. Value must be a string with no internal spaces, and should be a valid e-mail address.

If you expect to post more than 3 E-utility requests per second from a single IP address, consider including the following parameter:

### api_key

Value of the API key for sites that post more than 3 requests per second. Please see Chapter 2 for a full discussion of this policy.

## E-utilities DTDs

With the exception of EFetch, the E-utilities each generate a single XML output format that conforms to a DTD specific for that utility. Links to these DTDs are provided in the XML headers of the E-utility returns.

ESummary version 2.0 produces unique XML DocSums for each Entrez database, and as such each Entrez database has a unique DTD for version 2.0 DocSums. Links to these DTDs are provided in the version 2.0 XML.

EFetch produces output in a variety of formats, some of which are XML. Most of these XML formats also conform to DTDs or schema specific to the relevant Entrez database. Please follow the appropriate link below for the PubMed DTD:

- PubMed DTD June 2018 – current PubMed DTD (http://dtd.nlm.nih.gov/ncbi/pubmed/out/pubmed_180601.dtd)
- PubMed DTD January 2019 – forthcoming DTD (http://dtd.nlm.nih.gov/ncbi/pubmed/out/pubmed_190101.dtd)

## EInfo

### Base URL

https://eutils.ncbi.nlm.nih.gov/entrez/eutils/einfo.fcgi

### Functions

- Provides a list of the names of all valid Entrez databases
- Provides statistics for a single database, including lists of indexing fields and available link names

### Required Parameters

None. If no db parameter is provided, einfo will return a list of the names of all valid Entrez databases.

### Optional Parameters

#### db

Target database about which to gather statistics. Value must be a valid Entrez database name.

#### version

Used to specify version 2.0 EInfo XML. The only supported value is ‘2.0’. When present, EInfo will return XML that includes two new fields: <IsTruncatable> and <IsRangeable>. Fields that are truncatable allow the wildcard character ‘*’ in terms. The wildcard character will expand to match any set of characters up to a limit of 600 unique expansions. Fields that are rangeable allow the range operator ‘:’ to be placed between a lower and upper limit for the desired range (e.g. 2008:2010[pdat]).

#### retmode

Retrieval type. Determines the format of the returned output. The default value is ‘xml’ for EInfo XML, but ‘json’ is also supported to return output in JSON format.

### Examples

Return a list of all Entrez database names:

https://eutils.ncbi.nlm.nih.gov/entrez/eutils/einfo.fcgi

Return version 2.0 statistics for Entrez Protein:

https://eutils.ncbi.nlm.nih.gov/entrez/eutils/einfo.fcgi?db=protein&version=2.0

## ESearch

### Base URL

https://eutils.ncbi.nlm.nih.gov/entrez/eutils/esearch.fcgi

### Functions

- Provides a list of UIDs matching a text query
- Posts the results of a search on the History server
- Downloads all UIDs from a dataset stored on the History server
- Combines or limits UID datasets stored on the History server
- Sorts sets of UIDs

API users should be aware that some NCBI products contain search tools that generate content from searches on the web interface that are not available to ESearch. For example, the PubMed web interface (pubmed.ncbi.nlm.nih.gov) contains citation matching and spelling correction tools that are only available through that interface. Please see ECitMatch and ESpell below for API equivalents.

### Required Parameters

#### db

Database to search. Value must be a valid Entrez database name (default = pubmed).

#### term

Entrez text query. All special characters must be URL encoded. Spaces may be replaced by '+' signs. For very long queries (more than several hundred characters long), consider using an HTTP POST call. See the PubMed (https://pubmed.ncbi.nlm.nih.gov/help/) or Entrez help for information about search field descriptions and tags. Search fields and tags are database specific.

esearch.fcgi?db=pubmed&term=asthma

PubMed also offers “proximity searching (https://pubmed.ncbi.nlm.nih.gov/help/#proximity-searching)” for multiple terms appearing in any order within a specified number of words from one another in the [Title] or [Title/Abstract] fields.

esearch.fcgi?db=pubmed&term=”asthma treatment”[Title:~3]

### Optional Parameters – History Server

#### usehistory

When usehistory is set to 'y', ESearch will post the UIDs resulting from the search operation onto the History server so that they can be used directly in a subsequent E-utility call. Also, usehistory must be set to 'y' for ESearch to interpret query key values included in term or to accept a WebEnv as input.

#### WebEnv

Web environment string returned from a previous ESearch, EPost or ELink call. When provided, ESearch will post the results of the search operation to this pre-existing WebEnv, thereby appending the results to the existing environment. In addition, providing WebEnv allows query keys to be used in term so that previous search sets can be combined or limited. As described above, if WebEnv is used, usehistory must be set to 'y'.

esearch.fcgi?db=pubmed&term=asthma&WebEnv=<webenv string>&usehistory=y

#### query_key

Integer query key returned by a previous ESearch, EPost or ELink call. When provided, ESearch will find the intersection of the set specified by query_key and the set retrieved by the query in term (i.e. joins the two with AND). For query_key to function, WebEnv must be assigned an existing WebEnv string and usehistory must be set to 'y'.

Values for query keys may also be provided in term if they are preceeded by a '#' (%23 in the URL). While only one query_key parameter can be provided to ESearch, any number of query keys can be combined in term. Also, if query keys are provided in term, they can be combined with OR or NOT in addition to AND.

The following two URLs are functionally equivalent:esearch.fcgi?db=pubmed&term=asthma&query_key=1&WebEnv=<webenv string>&usehistory=yesearch.fcgi?db=pubmed&term=%231+AND+asthma&WebEnv=<webenv string>&usehistory=y

### Optional Parameters – Retrieval

#### retstart

Sequential index of the first UID in the retrieved set to be shown in the XML output (default=0, corresponding to the first record of the entire set). This parameter can be used in conjunction with retmax to download an arbitrary subset of UIDs retrieved from a search.

#### retmax

Total number of UIDs from the retrieved set to be shown in the XML output (default=20). By default, ESearch only includes the first 20 UIDs retrieved in the XML output. If usehistory is set to 'y', the remainder of the retrieved set will be stored on the History server; otherwise these UIDs are lost. Increasing retmax allows more of the retrieved UIDs to be included in the XML output, up to a maximum of 10,000 records.

To retrieve more than 10,000 UIDs from databases other than PubMed or PMC, submit multiple Esearch requests while incrementing the value of retstart (see Application 3). For PubMed and PMC, ESearch can only retrieve the first 10,000 records matching the query. To obtain more than 10,000 PubMed records, consider using EDirect (https://www.ncbi.nlm.nih.gov/books/NBK179288/#_chapter6_Local_PubMed_Cache_) that contains additional logic to batch PubMed search results automatically so that an arbitrary number can be retrieved. Alternatively, consider adding terms to your query (such as date limitations) to segment the desired set into batches of less than 10,000 records each.

#### rettype

Retrieval type. There are two allowed values for ESearch: 'uilist' (default), which displays the standard XML output, and 'count', which displays only the <Count> tag.

#### retmode

Retrieval type. Determines the format of the returned output. The default value is ‘xml’ for ESearch XML, but ‘json’ is also supported to return output in JSON format.

#### sort

Specifies the method used to sort UIDs in the ESearch output. The available values vary by database (db) and may be found in the Display Settings menu on an Entrez search results page. If usehistory is set to ‘y’, the UIDs are loaded onto the History Server in the specified sort order and will be retrieved in that order by ESummary or EFetch. Example values are ‘relevance’ and ‘name’ for Gene. Users should be aware that the default value of sort varies from one database to another, and that the default value used by ESearch for a given database may differ from that used on NCBI web search pages.

Values of sort for PubMed are as follows:

- pub_date – descending sort by publication date
- Author – ascending sort by first author
- JournalName – ascending sort by journal name
- relevance – default sort order, (“Best Match”) on web PubMed

#### field

Search field. If used, the entire search term will be limited to the specified Entrez field. The following two URLs are equivalent:

esearch.fcgi?db=pubmed&term=asthma&field=titleesearch.fcgi?db=pubmed&term=asthma[title]

#### idtype

Specifies the type of identifier to return for sequence databases (nuccore, popset, protein). By default, ESearch returns GI numbers in its output. If idtype is set to ‘acc’, ESearch will return accession.version identifiers rather than GI numbers.

### Optional Parameters – Dates

#### datetype

Type of date used to limit a search. The allowed values vary between Entrez databases, but common values are 'mdat' (modification date), 'pdat' (publication date) and 'edat' (Entrez date). Generally an Entrez database will have only two allowed values for datetype.

#### reldate

When reldate is set to an integer n, the search returns only those items that have a date specified by datetype within the last n days.

#### mindate, maxdate

Date range used to limit a search result by the date specified by datetype. These two parameters (mindate, maxdate) must be used together to specify an arbitrary date range. The general date format is YYYY/MM/DD, and these variants are also allowed: YYYY, YYYY/MM.

### Examples

Search in PubMed with the term cancer for abstracts that have an Entrez date within the last 60 days; retrieve the first 100 PMIDs and translations; post the results on the History server and return a WebEnv and query_key:

https://eutils.ncbi.nlm.nih.gov/entrez/eutils/esearch.fcgi?db=pubmed&term=cancer&reldate=60&datetype=edat&retmax=100&usehistory=y

Search in PubMed for the journal PNAS, Volume 97, and retrieve six PMIDs starting with the seventh PMID in the list:

https://eutils.ncbi.nlm.nih.gov/entrez/eutils/esearch.fcgi?db=pubmed&term=PNAS[ta]+AND+97[vi]&retstart=6&retmax=6&tool=biomed3 (https://eutils.ncbi.nlm.nih.gov/entrez/eutils/esearch.fcgi?db=pubmed&term=PNAS%5Bta%5D+AND+97%5Bvi%5D&retstart=6&retmax=6&tool=biomed3)

Search in the NLM Catalog for journals matching the term obstetrics:

https://eutils.ncbi.nlm.nih.gov/entrez/eutils/esearch.fcgi?db=nlmcatalog&term=obstetrics+AND+ncbijournals[filter] (https://eutils.ncbi.nlm.nih.gov/entrez/eutils/esearch.fcgi?db=nlmcatalog&term=obstetrics+AND+ncbijournals%5bfilter%5d)

Search PubMed Central for free full text articles containing the query stem cells:

https://eutils.ncbi.nlm.nih.gov/entrez/eutils/esearch.fcgi?db=pmc&term=stem+cells+AND+free+fulltext[filter] (https://eutils.ncbi.nlm.nih.gov/entrez/eutils/esearch.fcgi?db=pmc&term=stem+cells+AND+free+fulltext%5bfilter%5d)

Search in Nucleotide for all tRNAs:

https://eutils.ncbi.nlm.nih.gov/entrez/eutils/esearch.fcgi?db=nucleotide&term=biomol+trna[prop] (https://eutils.ncbi.nlm.nih.gov/entrez/eutils/esearch.fcgi?db=nucleotide&term=biomol+trna%5bprop%5d%20)

Search in Protein for a molecular weight range:

https://eutils.ncbi.nlm.nih.gov/entrez/eutils/esearch.fcgi?db=protein&term=70000:90000[molecular+weight] (https://eutils.ncbi.nlm.nih.gov/entrez/eutils/esearch.fcgi?db=protein&term=70000:90000%5bmolecular+weight%5d)

## EPost

### Base URL

https://eutils.ncbi.nlm.nih.gov/entrez/eutils/epost.fcgi

### Functions

- Uploads a list of UIDs to the Entrez History server
- Appends a list of UIDs to an existing set of UID lists attached to a Web Environment

### Required Parameters

#### db

Database containing the UIDs in the input list. The value must be a valid Entrez database name (default = pubmed).

#### id

UID list. Either a single UID or a comma-delimited list of UIDs may be provided. All of the UIDs must be from the database specified by db. For PubMed and PMC, no more than 10,000 UIDs can be included in a single URL request. For other databases there is no set maximum for the number of UIDs that can be passed to epost, but if more than about 200 UIDs are to be posted, the request should be made using the HTTP POST method.

For sequence databases (nuccore, popset, protein), the UID list may be a mixed list of GI numbers and accession.version identifiers. Note: When using accession.version identifiers, there is a conversion step that takes place that causes large lists of identifiers to time out, even when using POST. Therefore, we recommend batching these types of requests in sizes of about 500 UIDs or less, to avoid retrieving only a partial amount of records from your original POST input list.

epost.fcgi?db=pubmed&id=19393038,30242208,29453458epost.fcgi?db=protein&id=15718680,NP_001098858.1,119703751

### Optional Parameter

#### WebEnv

Web Environment. If provided, this parameter specifies the Web Environment that will receive the UID list sent by post. EPost will create a new query key associated with that Web Environment. Usually this WebEnv value is obtained from the output of a previous ESearch, EPost or ELink call. If no WebEnv parameter is provided, EPost will create a new Web Environment and post the UID list to query_key 1.

epost.fcgi?db=protein&id=15718680,157427902,119703751&WebEnv=<webenv string>

### Example

Post records to PubMed:

https://eutils.ncbi.nlm.nih.gov/entrez/eutils/epost.fcgi?db=pubmed&id=11237011,12466850

## ESummary

### Base URL

https://eutils.ncbi.nlm.nih.gov/entrez/eutils/esummary.fcgi

### Functions

- Returns document summaries (DocSums) for a list of input UIDs
- Returns DocSums for a set of UIDs stored on the Entrez History server

### Required Parameter

#### db

Database from which to retrieve DocSums. The value must be a valid Entrez database name (default = pubmed).

### Required Parameter – Used only when input is from a UID list

#### id

UID list. Either a single UID or a comma-delimited list of UIDs may be provided. All of the UIDs must be from the database specified by db. There is no set maximum for the number of UIDs that can be passed to ESummary, but if more than about 200 UIDs are to be provided, the request should be made using the HTTP POST method.

For sequence databases (nuccore, popset, protein), the UID list may be a mixed list of GI numbers and accession.version identifiers.

esummary.fcgi?db=pubmed&id=19393038,30242208,29453458esummary.fcgi?db=protein&id=15718680,NP_001098858.1,119703751

### Required Parameters – Used only when input is from the Entrez History server

#### query_key

Query key. This integer specifies which of the UID lists attached to the given Web Environment will be used as input to ESummary. Query keys are obtained from the output of previous ESearch, EPost or ELink calls. The query_key parameter must be used in conjunction with WebEnv.

#### WebEnv

Web Environment. This parameter specifies the Web Environment that contains the UID list to be provided as input to ESummary. Usually this WebEnv value is obtained from the output of a previous ESearch, EPost or ELink call. The WebEnv parameter must be used in conjunction with query_key.

esummary.fcgi?db=protein&query_key=<key>&WebEnv=<webenv string>

### Optional Parameters – Retrieval

#### retstart

Sequential index of the first DocSum to be retrieved (default=1, corresponding to the first record of the entire set). This parameter can be used in conjunction with retmax to download an arbitrary subset of DocSums from the input set.

#### retmax

Total number of DocSums from the input set to be retrieved, up to a maximum of 10,000. If the total set is larger than this maximum, the value of retstart can be iterated while holding retmax constant, thereby downloading the entire set in batches of size retmax.

#### retmode

Retrieval type. Determines the format of the returned output. The default value is ‘xml’ for ESummary XML, but ‘json’ is also supported to return output in JSON format.

#### version

Used to specify version 2.0 ESummary XML. The only supported value is ‘2.0’. When present, ESummary will return version 2.0 DocSum XML that is unique to each Entrez database and that often contains more data than the default DocSum XML.

### Examples

PubMed:

https://eutils.ncbi.nlm.nih.gov/entrez/eutils/esummary.fcgi?db=pubmed&id=11850928,11482001

PubMed, version 2.0 XML:

https://eutils.ncbi.nlm.nih.gov/entrez/eutils/esummary.fcgi?db=pubmed&id=11850928,11482001&version=2.0

Protein:

https://eutils.ncbi.nlm.nih.gov/entrez/eutils/esummary.fcgi?db=protein&id=28800982,28628843

Nucleotide:

https://eutils.ncbi.nlm.nih.gov/entrez/eutils/esummary.fcgi?db=nucleotide&id=28864546,28800981

Structure:

https://eutils.ncbi.nlm.nih.gov/entrez/eutils/esummary.fcgi?db=structure&id=19923,12120

Taxonomy:

https://eutils.ncbi.nlm.nih.gov/entrez/eutils/esummary.fcgi?db=taxonomy&id=9913,30521

UniSTS:

https://eutils.ncbi.nlm.nih.gov/entrez/eutils/esummary.fcgi?db=unists&id=254085,254086

## EFetch

### Base URL

https://eutils.ncbi.nlm.nih.gov/entrez/eutils/efetch.fcgi

### Functions

- Returns formatted data records for a list of input UIDs
- Returns formatted data records for a set of UIDs stored on the Entrez History server

### Required Parameters

#### db

Database from which to retrieve records. The value must be a valid Entrez database name (default = pubmed). Currently EFetch does not support all Entrez databases. Please see Table 1 in Chapter 2 for a list of available databases.

### Required Parameter – Used only when input is from a UID list

#### id

UID list. Either a single UID or a comma-delimited list of UIDs may be provided. All of the UIDs must be from the database specified by db. There is no set maximum for the number of UIDs that can be passed to EFetch, but if more than about 200 UIDs are to be provided, the request should be made using the HTTP POST method.

For sequence databases (nuccore, popset, protein), the UID list may be a mixed list of GI numbers and accession.version identifiers.

efetch.fcgi?db=pubmed&id=19393038,30242208,29453458efetch.fcgi?db=protein&id=15718680,NP_001098858.1,119703751

Special note for sequence databases.

NCBI is no longer assigning GI numbers to a growing number of new sequence records. As such, these records are not indexed in Entrez, and so cannot be retrieved using ESearch or ESummary, and have no Entrez links accessible by ELink. EFetch can retrieve these records by including their accession.version identifier in the id parameter.

### Required Parameters – Used only when input is from the Entrez History server

#### query_key

Query key. This integer specifies which of the UID lists attached to the given Web Environment will be used as input to EFetch. Query keys are obtained from the output of previous ESearch, EPost or ELInk calls. The query_key parameter must be used in conjunction with WebEnv.

#### WebEnv

Web Environment. This parameter specifies the Web Environment that contains the UID list to be provided as input to EFetch. Usually this WebEnv value is obtained from the output of a previous ESearch, EPost or ELink call. The WebEnv parameter must be used in conjunction with query_key.

efetch.fcgi?db=protein&query_key=<key>&WebEnv=<webenv string>

### Optional Parameters – Retrieval

#### retmode

Retrieval mode. This parameter specifies the data format of the records returned, such as plain text, HMTL or XML. See Table 1 for a full list of allowed values for each database.

#### rettype

Retrieval type. This parameter specifies the record view returned, such as Abstract or MEDLINE from PubMed, or GenPept or FASTA from protein. Please see Table 1 for a full list of allowed values for each database.

#### retstart

Sequential index of the first record to be retrieved (default=0, corresponding to the first record of the entire set). This parameter can be used in conjunction with retmax to download an arbitrary subset of records from the input set.

#### retmax

Total number of records from the input set to be retrieved, up to a maximum of 10,000. Optionally, for a large set the value of retstart can be iterated while holding retmax constant, thereby downloading the entire set in batches of size retmax.

### Optional Parameters – Sequence Databases

#### strand

Strand of DNA to retrieve. Available values are "1" for the plus strand and "2" for the minus strand.

#### seq_start

First sequence base to retrieve. The value should be the integer coordinate of the first desired base, with "1" representing the first base of the seqence.

#### seq_stop

Last sequence base to retrieve. The value should be the integer coordinate of the last desired base, with "1" representing the first base of the seqence.

#### complexity

Data content to return. Many sequence records are part of a larger data structure or "blob", and the complexity parameter determines how much of that blob to return. For example, an mRNA may be stored together with its protein product. The available values are as follows:

Value of complexity | Data returned for each requested GI
0 | entire blob
1 | bioseq
2 | minimal bioseq-set
3 | minimal nuc-prot
4 | minimal pub-set

### Examples

PubMed

Fetch PMIDs 17284678 and 9997 as text abstracts:

https://eutils.ncbi.nlm.nih.gov/entrez/eutils/efetch.fcgi?db=pubmed&id=17284678,9997&retmode=text&rettype=abstract

Fetch PMIDs in XML:

https://eutils.ncbi.nlm.nih.gov/entrez/eutils/efetch.fcgi?db=pubmed&id=11748933,11700088&retmode=xml

PubMed Central

Fetch XML for PubMed Central ID 212403:

https://eutils.ncbi.nlm.nih.gov/entrez/eutils/efetch.fcgi?db=pmc&id=212403

Nucleotide/Nuccore

Fetch the first 100 bases of the plus strand of GI 21614549 in FASTA format:

https://eutils.ncbi.nlm.nih.gov/entrez/eutils/efetch.fcgi?db=nuccore&id=21614549&strand=1&seq_start=1&seq_stop=100&rettype=fasta&retmode=text

Fetch the first 100 bases of the minus strand of GI 21614549 in FASTA format:

https://eutils.ncbi.nlm.nih.gov/entrez/eutils/efetch.fcgi?db=nuccore&id=21614549&strand=2&seq_start=1&seq_stop=100&rettype=fasta&retmode=text

Fetch the nuc-prot object for GI 21614549:

https://eutils.ncbi.nlm.nih.gov/entrez/eutils/efetch.fcgi?db=nuccore&id=21614549&complexity=3

Fetch the full ASN.1 record for GI 5:

https://eutils.ncbi.nlm.nih.gov/entrez/eutils/efetch.fcgi?db=nucleotide&id=5

Fetch FASTA for GI 5:

https://eutils.ncbi.nlm.nih.gov/entrez/eutils/efetch.fcgi?db=nucleotide&id=5&rettype=fasta

Fetch the GenBank flat file for GI 5:

https://eutils.ncbi.nlm.nih.gov/entrez/eutils/efetch.fcgi?db=nucleotide&id=5&rettype=gb

Fetch GBSeqXML for GI 5:

https://eutils.ncbi.nlm.nih.gov/entrez/eutils/efetch.fcgi?db=nucleotide&id=5&rettype=gb&retmode=xml

Fetch TinySeqXML for GI 5:

https://eutils.ncbi.nlm.nih.gov/entrez/eutils/efetch.fcgi?db=nucleotide&id=5&rettype=fasta&retmode=xml

Popset

Fetch the GenPept flat file for Popset ID 12829836:

https://eutils.ncbi.nlm.nih.gov/entrez/eutils/efetch.fcgi?db=popset&id=12829836&rettype=gp

Protein

Fetch the GenPept flat file for GI 8:

https://eutils.ncbi.nlm.nih.gov/entrez/eutils/efetch.fcgi?db=protein&id=8&rettype=gp

Fetch GBSeqXML for GI 8:

https://eutils.ncbi.nlm.nih.gov/entrez/eutils/efetch.fcgi?db=protein&id=8&rettype=gp&retmode=xml

Sequences

Fetch FASTA for a transcript and its protein product (GIs 312836839 and 34577063)

https://eutils.ncbi.nlm.nih.gov/entrez/eutils/efetch.fcgi?db=sequences&id=312836839,34577063&rettype=fasta&retmode=text

Gene

Fetch full XML record for Gene ID 2:

https://eutils.ncbi.nlm.nih.gov/entrez/eutils/efetch.fcgi?db=gene&id=2&retmode=xml

## ELink

### Base URL

https://eutils.ncbi.nlm.nih.gov/entrez/eutils/elink.fcgi

### Functions

- Returns UIDs linked to an input set of UIDs in either the same or a different Entrez database
- Returns UIDs linked to other UIDs in the same Entrez database that match an Entrez query
- Checks for the existence of Entrez links for a set of UIDs within the same database
- Lists the available links for a UID
- Lists LinkOut URLs and attributes for a set of UIDs
- Lists hyperlinks to primary LinkOut providers for a set of UIDs
- Creates hyperlinks to the primary LinkOut provider for a single UID

### Required Parameters

#### Specifying the desired link (linkname, db, dbfrom)

Option 1 (preferred): linkname

Using linkname is the most efficient option as ELink will retrieve data for only that single link type.

linkname: Name of the Entrez link to retrieve. Every link in Entrez is given a name of the form

dbfrom_db_subset.

The values of subset vary depending on the values of dbfrom and db. Many dbfrom/db combinations have no subset values. See the list of Entrez links (https://eutils.ncbi.nlm.nih.gov/entrez/query/static/entrezlinks.html) for a listing of all available linknames. When linkname is used, only the links with that name will be retrieved.

The linkname parameter only functions when cmd is set to neighbor or neighbor_history.

Find RefSeq proteins linked to a gene.

https://eutils.ncbi.nlm.nih.gov/entrez/eutils/elink.fcgi?id=93986&linkname=gene_protein_refseq

Option 2: db and dbfrom

Using db and/or dbfrom will retrieve all available link types between dbfrom and db. ELink will assign the value pubmed to either parameter if that parameter is omitted. If linkname is included, ELink will ignore both db and dbfrom.

db: Database from which to retrieve UIDs. The value must be a valid Entrez database name (default = pubmed). This is the destination database for the link operation.

#### dbfrom: Database containing the input UIDs. The value must be a valid Entrez database name (default = pubmed). This is the origin database of the link operation. If db and dbfrom are set to the same database value, then ELink will return computational neighbors within that database. Please see the full list of Entrez links (https://eutils.ncbi.nlm.nih.gov/entrez/query/static/entrezlinks.html) for available computational neighbors. Computational neighbors have linknames that begin with dbname_dbname (examples: protein_protein, pcassay_pcassay_activityneighbor).

Find all proteins linked to a gene.

https://eutils.ncbi.nlm.nih.gov/entrez/eutils/elink.fcgi?dbfrom=gene&db=protein&id=93986

#### cmd

ELink command mode. The command mode specified which function ELink will perform. Some optional parameters only function for certain values of &cmd (see below).

cmd=neighbor (default)

ELink returns a set of UIDs in db linked to the input UIDs in dbfrom.

Example: Link from protein to gene

https://eutils.ncbi.nlm.nih.gov/entrez/eutils/elink.fcgi?dbfrom=protein&db=gene&id=15718680,157427902

cmd=neighbor_score

ELink returns a set of UIDs within the same database as the input UIDs along with computed similarity scores.

Example: Find related articles to PMID 20210808

https://eutils.ncbi.nlm.nih.gov/entrez/eutils/elink.fcgi?dbfrom=pubmed&db=pubmed&id=20210808&cmd=neighbor_score

cmd=neighbor_history

ELink posts the output UIDs to the Entrez History server and returns a query_key and WebEnv corresponding to the location of the output set.

Example: Link from protein to gene and post the results on the Entrez History

https://eutils.ncbi.nlm.nih.gov/entrez/eutils/elink.fcgi?dbfrom=protein&db=gene&id=15718680,157427902&cmd=neighbor_history

cmd=acheck

ELink lists all links available for a set of UIDs.

Example: List all possible links from two protein GIs

https://eutils.ncbi.nlm.nih.gov/entrez/eutils/elink.fcgi?dbfrom=protein&id=15718680,157427902&cmd=acheck

Example: List all possible links from two protein GIs to PubMed

https://eutils.ncbi.nlm.nih.gov/entrez/eutils/elink.fcgi?dbfrom=protein&db=pubmed&id=15718680,157427902&cmd=acheck

cmd=ncheck

ELink checks for the existence of links within the same database for a set of UIDs. These links are equivalent to setting db and dbfrom to the same value.

Example: Check whether two nuccore sequences have "related sequences" links.

https://eutils.ncbi.nlm.nih.gov/entrez/eutils/elink.fcgi?dbfrom=nuccore&id=21614549,219152114&cmd=ncheck

cmd=lcheck

Elink checks for the existence of external links (LinkOuts) for a set of UIDs.

Example: Check whether two protein sequences have any LinkOut providers.

https://eutils.ncbi.nlm.nih.gov/entrez/eutils/elink.fcgi?dbfrom=protein&id=15718680,157427902&cmd=lcheck

cmd=llinks

For each input UID, ELink lists the URLs and attributes for the LinkOut providers that are not libraries.

Example: List the LinkOut URLs for non-library providers for two pubmed abstracts.

https://eutils.ncbi.nlm.nih.gov/entrez/eutils/elink.fcgi?dbfrom=pubmed&id=19880848,19822630&cmd=llinks

cmd=llinkslib

For each input UID, ELink lists the URLs and attributes for all LinkOut providers including libraries.

Example: List all LinkOut URLs for two PubMed abstracts.

https://eutils.ncbi.nlm.nih.gov/entrez/eutils/elink.fcgi?dbfrom=pubmed&id=19880848,19822630&cmd=llinkslib

cmd=prlinks

ELink lists the primary LinkOut provider for each input UID, or links directly to the LinkOut provider's web site for a single UID if retmode is set to ref.

Example: Find links to full text providers for two PubMed abstracts.

https://eutils.ncbi.nlm.nih.gov/entrez/eutils/elink.fcgi?dbfrom=pubmed&id=19880848,19822630&cmd=prlinks

Example: Link directly to the full text for a PubMed abstract at the provider's web site.

https://eutils.ncbi.nlm.nih.gov/entrez/eutils/elink.fcgi?dbfrom=pubmed&id=19880848&cmd=prlinks&retmode=ref

### Required Parameter – Used only when input is from a UID list

#### id

UID list. Either a single UID or a comma-delimited list of UIDs may be provided. All of the UIDs must be from the database specified by dbfrom. There is no set maximum for the number of UIDs that can be passed to ELink, but if more than about 200 UIDs are to be provided, the request should be made using the HTTP POST method.

Link from protein to gene.

https://eutils.ncbi.nlm.nih.gov/entrez/eutils/elink.fcgi?dbfrom=protein&db=gene&id=15718680,157427902,119703751

Find related sequences (link from nuccore to nuccore).

https://eutils.ncbi.nlm.nih.gov/entrez/eutils/elink.fcgi?dbfrom=nuccore&db=nuccore&id=34577062

If more than one id parameter is provided, ELink will perform a separate link operation for the set of UIDs specified by each id parameter. This effectively accomplishes "one-to-one" links and preserves the connection between the input and output UIDs.

Find one-to-one links from protein to gene.

https://eutils.ncbi.nlm.nih.gov/entrez/eutils/elink.fcgi?dbfrom=protein&db=gene&id=15718680&id=157427902&id=119703751

For sequence databases (nuccore, popset, protein), the UID list may be a mixed list of GI numbers and accession.version identifiers.

Find one-to-one links from protein to gene.

https://eutils.ncbi.nlm.nih.gov/entrez/eutils/elink.fcgi?dbfrom=protein&db=gene&id=15718680&id=NP_001098858.1&id=119703751

### Required Parameters – Used only when input is from the Entrez History server

#### query_key

Query key. This integer specifies which of the UID lists attached to the given Web Environment will be used as input to ELink. Query keys are obtained from the output of previous ESearch, EPost or ELInk calls. The query_key parameter must be used in conjunction with WebEnv.

#### WebEnv

Web Environment. This parameter specifies the Web Environment that contains the UID list to be provided as input to ELink. Usually this WebEnv value is obtained from the output of a previous ESearch, EPost or ELink call. The WebEnv parameter must be used in conjunction with query_key.

Link from protein to gene:elink.fcgi?dbfrom=protein&db=gene&query_key=<key>&WebEnv=<webenv string>Find related sequences (link from protein to protein):elink.fcgi?dbfrom=protein&db=protein&query_key=<key>&WebEnv=<webenv string>

### Optional Parameter – Retrieval

#### retmode

Retrieval type. Determines the format of the returned output. The default value is ‘xml’ for ELink XML, but ‘json’ is also supported to return output in JSON format.

#### idtype

Specifies the type of identifier to return for sequence databases (nuccore, popset, protein). By default, ELink returns GI numbers in its output. If idtype is set to ‘acc’, ELink will return accession.version identifiers rather than GI numbers.

### Optional Parameters – Limiting the Output Set of Links

#### term

Entrez query used to limit the output set of linked UIDs. The query in the term parameter will be applied after the link operation, and only those UIDs matching the query will be returned by ELink. The term parameter only functions when db and dbfrom are set to the same database value.

Find all related articles for a PMID.

https://eutils.ncbi.nlm.nih.gov/entrez/eutils/elink.fcgi?dbfrom=pubmed&db=pubmed&id=19879512

Find all related review articles published in 2008 for a PMID.

https://eutils.ncbi.nlm.nih.gov/entrez/eutils/elink.fcgi?dbfrom=pubmed&db=pubmed&id=19879512&term=review%5Bfilter%5D+AND+2008%5Bpdat%5Dh (https://eutils.ncbi.nlm.nih.gov/entrez/eutils/elink.fcgi?dbfrom=pubmed&db=pubmed&id=19879512&term=review%5Bfilter%5D+AND+2008%5Bpdat%5D)

#### holding

Name of LinkOut provider. Only URLs for the LinkOut provider specified by holding will be returned. The value provided to holding should be the abbreviation of the LinkOut provider's name found in the <NameAbbr> tag of the ELink XML output when cmd is set to llinks or llinkslib. The holding parameter only functions when cmd is set to llinks or llinkslib.

Find information for all LinkOut providers for a PMID.

https://eutils.ncbi.nlm.nih.gov/entrez/eutils/elink.fcgi?dbfrom=pubmed&cmd=llinkslib&id=16210666

Find information from clinicaltrials.gov for a PMID.

https://eutils.ncbi.nlm.nih.gov/entrez/eutils/elink.fcgi?dbfrom=pubmed&cmd=llinkslib&id=16210666&holding=CTgov

### Optional Parameters – Dates

These parameters only function when cmd is set to neighbor or neighbor_history and dbfrom is pubmed.

#### datetype

Type of date used to limit a link operation. The allowed values vary between Entrez databases, but common values are 'mdat' (modification date), 'pdat' (publication date) and 'edat' (Entrez date). Generally an Entrez database will have only two allowed values for datetype.

#### reldate

When reldate is set to an integer n, ELink returns only those items that have a date specified by datetype within the last n days.

#### mindate, maxdate

Date range used to limit a link operation by the date specified by datetype. These two parameters (mindate, maxdate) must be used together to specify an arbitrary date range. The general date format is YYYY/MM/DD, and these variants are also allowed: YYYY, YYYY/MM.

## EGQuery

### Base URL

https://eutils.ncbi.nlm.nih.gov/entrez/eutils/egquery.fcgi

### Function

Provides the number of records retrieved in all Entrez databases by a single text query.

### Required Parameter

#### term

Entrez text query. All special characters must be URL encoded. Spaces may be replaced by '+' signs. For very long queries (more than several hundred characters long), consider using an HTTP POST call. See the PubMed or Entrez help for information about search field descriptions and tags. Search fields and tags are database specific.

https://eutils.ncbi.nlm.nih.gov/entrez/eutils/egquery.fcgi?term=asthma

## ESpell

### Base URL

https://eutils.ncbi.nlm.nih.gov/entrez/eutils/espell.fcgi

### Function

Provides spelling suggestions for terms within a single text query in a given database.

### Required Parameters

#### db

Database to search. Value must be a valid Entrez database name (default = pubmed).

#### term

Entrez text query. All special characters must be URL encoded. Spaces may be replaced by '+' signs. For very long queries (more than several hundred characters long), consider using an HTTP POST call. See the PubMed or Entrez help for information about search field descriptions and tags. Search fields and tags are database specific.

https://eutils.ncbi.nlm.nih.gov/entrez/eutils/espell.fcgi?db=pubmed&term=asthmaa+OR+alergies

## ECitMatch

### Base URL

https://eutils.ncbi.nlm.nih.gov/entrez/eutils/ecitmatch.cgi

### Function

Retrieves PubMed IDs (PMIDs) that correspond to a set of input citation strings.

### Required Parameters

#### db

Database to search. The only supported value is ‘pubmed’.

#### rettype

Retrieval type. The only supported value is ‘xml’.

#### bdata

Citation strings. Each input citation must be represented by a citation string in the following format:

journal_title|year|volume|first_page|author_name|your_key|

Multiple citation strings may be provided by separating the strings with a carriage return character (%0D). The your_key value is an arbitrary label provided by the user that may serve as a local identifier for the citation, and it will be included in the output. Be aware that all spaces must be replaced by ‘+’ symbols and that citation strings should end with a final vertical bar ‘|’.

https://eutils.ncbi.nlm.nih.gov/entrez/eutils/ecitmatch.cgi?db=pubmed&retmode=xml&bdata=proc+natl+acad+sci+u+s+a|1991|88|3248|mann+bj|Art1|%0Dscience|1987|235|182|palmenberg+ac|Art2|

## Release Notes

### EFetch; ELink JSON ouput: June 24, 2015

- EFetch now supports ClinVar and GTR
- ELink now provides output in JSON format

### ESearch &sort; JSON output format: February 14, 2014

- ESearch now provides a supported sort parameter
- EInfo, ESearch and ESummary now provide output data in JSON format

### ECitMatch, EInfo Version 2.0, EFetch: August 9, 2013

- ECitMatch is a new E-utility that serves as an API to the PubMed batch citation matcher (https://www.ncbi.nlm.nih.gov/pubmed/batchcitmatch)
- EInfo has an updated XML output that includes two new fields: <IsTruncatable> and <IsRangeable>
- EFetch now supports the BioProject database.

### EFetch Version 2.0. Target release date: February 15, 2012

- EFetch now supports the following databases: biosample, biosystems and sra
- EFetch now has defined default values for &retmode and &rettype for all supported databases (please see Table 1 for all supported values of these parameters)
- EFetch no longer supports &retmode=html; requests containing &retmode=html will return data using the default &retmode value for the specified database (&db)
- EFetch requests including &rettype=docsum return XML data equivalent to ESummary output

### Release of new Genome database: November 9, 2011

- Entrez Genome has been completely redesigned, and database records now correspond to a species rather than an individual chromosome sequence. Please see full details of the change at https://www.ncbi.nlm.nih.gov/About/news/17Nov2011.html
- Old Genome IDs are no longer valid. A file is available on the NCBI FTP site that maps old Genome IDs to Nucleotide GIs: ftp.ncbi.nih.gov/genomes/old_genomeID2nucGI
- EFetch no longer supports retrievals from Genome (db=genome).
- The ESummary XML for Genome has been recast to reflect the new data model.
- To view the new search fields and links supported for the new Genome database, please see https://eutils.ncbi.nlm.nih.gov/entrez/eutils/einfo.fcgi?db=genome

### ESummary Version 2.0. November 4, 2011

- ESummary now supports a new, alternative XML presentation for Entrez document summaries (DocSums). The new XML is unique to each Entrez database and generally contains more extensive data about the record than the original DocSum XML.
- There are no plans at present to discontinue the original DocSum XML, so developers can continue to use this presentation, which will remain the default.
- Version 2.0 XML is returned when &version=2.0 is included in the ESummary URL.

## Demonstration Programs

Please see Chapter 1 for sample Perl scripts.

## For More Information

Please see Chapter 1 for getting additional information about the E-utilities.

Table 1

– Valid values of &retmode and &rettype for EFetch (null = empty string)

Record Type | &rettype | &retmode
All Databases
Document summary | docsum | xml, default
List of UIDs in XML | uilist | xml
List of UIDs in plain text | uilist | text
db = bioproject
Full record XML | xml, default | xml, default
db = biosample
Full record XML | full, default | xml, default
Full record text | full, default | text
db = gds
Summary | summary, default | text, default
db = gene
text ASN.1 | null | asn.1, default
XML | null | xml
Gene table | gene_table | text
db = homologene
text ASN.1 | null | asn.1, default
XML | null | xml
Alignment scores | alignmentscores | text
FASTA | fasta | text
HomoloGene | homologene | text
db = mesh
Full record | full, default | text, default
db = nlmcatalog
Full record | null | text, default
XML | null | xml
db = nuccore, protein or popset
text ASN.1 | null | text, default
binary ASN.1 | null | asn.1
Full record in XML | native | xml
Accession number(s) | acc | text
FASTA | fasta | text
TinySeq XML | fasta | xml
SeqID string | seqid | text
Additional options for db = nuccore or popset
GenBank flat file | gb | text
GBSeq XML | gb | xml
INSDSeq XML | gbc | xml
Additional option for db = nuccore and protein
Feature table | ft | text
Additional option for db = nuccore
GenBank flat file with full sequence (contigs) | gbwithparts | text
CDS nucleotide FASTA | fasta_cds_na | text
CDS protein FASTA | fasta_cds_aa | text
Additional options for db = protein
GenPept flat file | gp | text
GBSeq XML | gp | xml
INSDSeq XML | gpc | xml
Identical Protein XML | ipg | xml
db = pmc
XML | null | xml, default
MEDLINE | medline | text
db = pubmed
XML | null | xml, default
MEDLINE | medline | text
PMID list | uilist | text
Abstract | abstract | text
db = sequences
text ASN.1 | null | text, default
Accession number(s) | acc | text
FASTA | fasta | text
SeqID string | seqid | text
db = snp
text ASN.1 | null | asn.1, default
XML | null | xml
Flat file | flt | text
FASTA | fasta | text
RS Cluster report | rsr | text
SS Exemplar list | ssexemplar | text
Chromosome report | chr | text
Summary | docset | text
UID list | uilist | text or xml
db = sra
XML | full, default | xml, default
db = taxonomy
XML | null | xml, default
TaxID list | uilist | text or xml
db = clinvar
ClinVar Set | clinvarset | xml, default
UID list | uilist | text or xml
db = gtr
GTR Test Report | gtracc | xml, default