# NIH ICs that Support GWAS

Could you provide a list of NIH ICs that support GWAS?

The following NIH Institutes and Centers (ICs) support Genome Wide Association Studies (GWAS):

National Cancer Institute (NCI) (http://www.cancer.gov/)

National Center for Research Resources (NCRR) (http://www.ncrr.nih.gov/)

National Eye Institute (NEI) (http://www.nei.nih.gov/)

National Human Genome Research Institute (NHGRI) (http://www.genome.gov/)

National Heart, Lung, and Blood Institute (NHLBI) (http://www.nhlbi.nih.gov/)

National Institute on Aging (NIA) (http://www.nia.nih.gov/)

National Institute of Allergy and Infectious Diseases (NIAID) (http://www.niaid.nih.gov/Pages/default.aspx)

National Institute of Arthritis and Musculoskeletal and Skin Diseases (NIAMS) (http://www.niams.nih.gov/)

National Institute of Biomedical Imaging and Bioengineering (NIBIB) (http://www.nibib.nih.gov/)

National Institute of Child Health and Human Development (NICHD) (http://www.nichd.nih.gov/)

National Institute on Drug Abuse (NIDA) (http://www.nida.nih.gov/nidahome.html)

National Institute on Deafness and Other Communication Disorders (NIDCD) (http://www.nidcd.nih.gov/Pages/default.aspx)

National Institute of Dental and Craniofacial Research (NIDCR) (http://www.nidcr.nih.gov/)

National Institute of Diabetes and Digestive and Kidney Diseases (NIDDK) (http://www.nidcr.nih.gov/)

National Institute of Environmental Health Sciences (NIEHS) (http://www.niehs.nih.gov/)

National Institute of General Medical Sciences (NIGMS) (http://www.nigms.nih.gov/)

National Institute of Mental Health (NIMH) (http://www.nimh.nih.gov/index.shtml)

National Institute on Minority Health and Health Disparities (NIMHD) (http://www.nimhd.nih.gov/)

National Institute of Neurological Disorders and Stroke (NINDS) (http://www.ninds.nih.gov/)

National Institute of Nursing Research (NINR) (http://www.ninr.nih.gov/)

(11/17/2011)