# Beginning the Submission Process

The dbGaP study registration and data submission process

An outline of steps of dbGaP study registration and data submission can be found from here (http://www.ncbi.nlm.nih.gov/projects/gap/cgi-bin/GetPdf.cgi?document_name=HowToSubmit.pdf).

(04/04/2014)