# Submitting to dbGaP

This section of the dbGaP FAQ Archive contains general information about the dbGaP submission process.

To begin searching this section of the dbGaP FAQ Archive, you can either:

- Enter your search word(s) text in the text box at the top of the page and click on the “Go” button,

OR

- Click on any of the “Submitting to dbGaP” sub-categories listed in the navigation box on the right side of the page to navigate to the sub-category of your choice.