# How to Search for Specific Information in a Particular Study

## Finding Variables Represented in a Specific Study.

How do I find out if the Framingham SHARe data includes alcohol use and smoking as variables?

You can query the dbGaP system directly to see a short list of the variables in which you are interested. Below are the steps for an example query to get you started:

1 Go to the NEI Age-Related Eye Disease Study (AREDS) (http://www.ncbi.nlm.nih.gov/projects/gap/cgi-bin/study.cgi?study_id=phs000001.v2.p1) , and type “smoking” (do not use quotation marks) into the “Search Within This Study” box, located on the right side of the page, and press “go”.
2 The results (http://www.ncbi.nlm.nih.gov/sites/entrez?cmd=search&db=gap&studyId=phs000001.v2.p1+&term=(smoking)+AND+phs000001.v2.p1+%5bs_ancestor%5d&searchText=smoking) of this search is shown under a series of tabs labeled “Studies”, “Variables”, “Study Documents”, and “Analyses”. The number shown in parentheses next to the tab label is the number of items matching your query.
3 You can use the AND, OR, and NOT operators to make more complex queries to the system (e.g. smoking AND alcohol (http://www.ncbi.nlm.nih.gov/sites/entrez?cmd=search&db=gap&studyId=phs000001.v2.p1+&term=(smoking+AND+alcohol)+AND+phs000001.v2.p1+%5bs_ancestor%5d&searchText=smoking+AND+alcohol)). (08/14/08)