# Is Institutional Affiliation Required for Data Access?

I want to use individual-level data to validate the code of a testing tool. Do I need institutional affiliation to access this data? Can I access non-human data instead?

You must have an institutional affiliation and research credentials to request individual level human data from dbGaP. (08/22/08)