# Informed Consent for Genomic Research

Would you provide some model informed consent language for studies which have a dbGaP reporting requirement?

The dbGaP data distribution is governed by the NIH GDS policy. There is some information about informed consent for genomic research on NHGRI website that may be useful to you. The following is how to get there:

From the NHGRI website (http://www.genome.gov/), click on the “Issues in Genetics” tab and select “Informed Consent for Genomic Research”. The specific link that may be relevant is to this (http://www.genome.gov/27526660) page.

(08/22/2014)