# Data Sharing Policy

## Data Sharing Policy

What data sharing policy one should follow when using the dbGaP data?

NIH Policy for Sharing of Data Obtained in NIH supported or conducted Genomic Data Sharing Policy (GDS Policy) also referred to as the “GDS Policy” is published on the NIH GDS website (https://sharing.nih.gov/genomic-data-sharing-policy). General questions about the GDS policy should be addressed to gds@mail.nih.gov.

(08/22/2014)