# Citing dbGaP in a Publication

How do I cite dbGaP in the “Reference” section of a publication I am writing?

When you write a manuscript and report data that

1 are based on the use of dbGaP study data, accessed and/or downloaded from the dbGaP web site (public pages for general and summary information or Authorized Access pages for subject-level data), please cite the USE of dbGaP study data in your manuscript by referencing the study accession (phs#), and the data use, and provide a link to the appropriate study page if at all possible, using a format like this:The data/analyses presented in the current publication are based on the use of study data downloaded from the dbGaP web site, under phsxxxxxx.vx.px (e.g. phs000001.v1.p1/https://www.ncbi.nlm.nih.gov/projects/gap/cgi-bin/study.cgi?study_id=phs000001.v3.p1);
2 are based on data that you uploaded to the dbGaP database, please reference the data upload using a format like this:The data/analyses presented in the current publication have been deposited in and are available from the dbGaP database under dbGaP accession phsxxxxxx.vx.px (e.g. phs001233.v1.p1).

When you have used or deposited data of more than one dbGaP study, please reference each dbGaP study separately, e.g.:

- The data/analyses presented in the current publication are based on the use of study data downloaded from the dbGaP web site, under dbGaP accession e.g. phs000001.v1.p1, phs000002.v1.p1, phs000003.v1.p1;
- The data/analyses presented in the current publication have been deposited in and are available from the dbGaP database under dbGaP accession e.g. phs001233.v1.p1, phs001234.v1.p1.

When you are citing the dbGaP database in general, without reference to specific studies, please use a format like this: dbGaP/database of Genotypes and Phenotypes/ National Center for Biotechnology Information, National Library of Medicine (NCBI/NLM)/https://www.ncbi.nlm.nih.gov/gap

When appropriate, please add dbGaP references, e.g.:

The NCBI dbGaP Database of Genotypes and Phenotypes. Mailman MD, Feolo M, Jin Y, Kimura M, Tryka K, Bagoutdinov R, Hao L,

Kiang A, Paschall J, Phan L, Popova N, Pretel S, Ziyabari L, Lee M, Shao Y, Wang ZY, Sirotkin K, Ward M, Kholodov M, Zbicz K, Beck J, Kimelman M, Shevelev S, Preuss D, Yaschenko E, Graeff A, Ostell J, Sherry ST.

Nat Genet. 2007 Oct; 39(10):1181-6.

NCBI's Database of Genotypes and Phenotypes: dbGaP.

Tryka KA, Hao L, Sturcke A, Jin Y, Wang ZY, Ziyabari L, Lee M, Popova N, Sharopova N, Kimura M, Feolo M.

Nucleic Acids Res. 2014 Jan; 42 (Database issue): D975-9.

(01/06/17)