# General Information regarding dbGaP Data Access

This section of the dbGaP FAQ Archive contains general information about accessing data in dbGaP that range from determining where the data you are looking for is located and the definition of “Embargo Release Dates”, to the need for institutional affiliation to access data and how to manage your eRA passwords.

To begin searching this section of the dbGaP FAQ Archive, you can either:

- Enter your search word(s) text in the text box at the top of the page and click on the “Go” button,

OR

- Click on any of the “General Information regarding dbGaP Data Access” sub-categories listed in the navigation box on the right side of the page to navigate to the sub-category of your choice.