# Data Access Requests

This section of the database of Genotypes and Phenotypes (dbGaP) FAQ Archive contains general information about completing and submitting a Data Access Request (DAR) that, once approved, will allow you authorized access to dbGaP’s controlled-access data. The information in this section ranges from password management, to a quick step-by step of how to complete the DAR and electronically sign it. This section also provides instructions about altering a completed and signed DAR, and information about password and request management for Signing Officials (SOs).

To begin searching this section of the dbGaP FAQ Archive, you can either:

- Enter your search word(s) text in the text box at the top of the page and click on the “Go” button,

OR

- Click on any of the “Data Access Requests” sub-categories listed in the navigation box on the right side of the page to navigate to the sub-category of your choice.