# Contact Information

## Contacting dbGaP

I have several questions regarding an application to dbGaP. What e-mail address should I send my inquiry to?

dbgap-help@ncbi.nlm.nih.gov is the correct email address for questions about the application process. General questions about the NIH Genomic Data Sharing (GDS) policy should be addressed to gds@mail.nih.gov.

(08/22/14)

## Contacting Data Access Committee (DAC)

Where can I find the DAC (Data Access Committee) email address of a study?

The DAC email address can be found either in the dbGaP Authorized Access System (https://dbgap.ncbi.nlm.nih.gov/) or on the dbGaP website.

For the former, once logging in to the dbGaP account, go to the “My Requests” tab, the DAC name (such as NHGRI, GAIN, TCGA …) is listed in the “Data set” column of the data request table. Click on the name, the email editor with the DAC email address will be opened. On the dbGaP website, the email address of the Data Access Committee (DAC) for a specific study is located in the “Authorized Access” section of the Study page (circled in red below):

[image]

(08/29/2012)

## Contact for Short Read Archive (SRA ) Related Questions

I have some questions related to the Short Read Archive (SRA ) data distributed through the dbGaP. What e-mail address should I send my inquiry to?

If your question is about SRA data availability or release status, please see here for more information. The SRA data may include the Next-Gen sequence raw data, BAM files, or other high throughput data. The SRA data distributed through dbGaP is handled and processed by the National Center for Biotechnology Information’s (NCBI’s) SRA group. The SRA group, thus, is in a better position to answer most of the SRA-related questions, especially those about SRA data submission, availability, and quality. The SRA help email address is sra@ncbi.nlm.nih.gov (06/14/2011)

## Contact for SRA Toolkit Related Questions

I tried to install sra_sdk-2.1.10 but got some errors. Where should I look for help?

The SRA toolkit can be downloaded from here (http://www.ncbi.nlm.nih.gov/Traces/sra/?view=software). The best contact for any SRA toolkit related issues is sra-tools@ncbi.nlm.nih.gov, a mailing list documented in every README within the source downloaded by users.

(07/10/2012)