# Data Content

This section of the dbGaP FAQ Archive contains general information about the nature of the data contained in dbGaP: information about the characteristics of a specific study’s data; general information that applies to all data sets; as well as whether or not certain types of data or tools are part of dbGaP’s content.

To begin searching this section of the dbGaP FAQ Archive, you can either:

- Enter your search word(s) text in the text box at the top of the page and click on the “Go” button,
  OR
- Click on any of the “Data Content” sub-categories listed in the navigation box on the right side of the page to navigate to the sub-category of your choice.