# Tutorials

This chapter contains a collection of short video tutorials that highlight the features of the Bookshelf.

## Tutorial 1: Browsing

A student is just beginning his course in biology, and his teacher has recommended Bookshelf as a good source of information. The student explores which books are relevant to his studies.

Tutorial 1. Browsing

Download transcript.

Watch on YouTube (https://www.youtube.com/watch?v=G4nIPDsQ06U&list=PL7dF9e2qSW0biNRqZ2UpiDxt_0I9JaNdC&index=1).

## Tutorial 2: Search

A medical student is trying to understand the role of the t-cell receptor during a viral infection.

Tutorial 2. Search

Download transcript.

Watch on YouTube (https://www.youtube.com/watch?v=7o_ai-vUA6o&list=PL7dF9e2qSW0biNRqZ2UpiDxt_0I9JaNdC&index=2).

## Tutorial 3: Inside a book

A genetics counselor is seeking information on hemochromatosis. He visits GeneReviews to learn about how the disease is inherited, and the risk to family members.

Tutorial 3. Inside a book

Download transcript.

Watch on YouTube (https://www.youtube.com/watch?v=fRikaDq6X40&list=PL7dF9e2qSW0biNRqZ2UpiDxt_0I9JaNdC&index=4).

## Tutorial 4: Using facets

A user needs to narrow results while seeking information otitis media.

Tutorial 4. Using facets

Download transcript.

Watch on YouTube (https://www.youtube.com/watch?v=AWogiEefht4&list=PL7dF9e2qSW0biNRqZ2UpiDxt_0I9JaNdC&index=3).

## Tutorial 5: Advanced search

A doctor is researching breast cancer. She wants to know about the BRCA gene and the drug tamoxifen.

Tutorial 5. Advanced search

Download transcript.

Watch on YouTube (https://www.youtube.com/watch?v=iY4MoZ_Tzr4&list=PL7dF9e2qSW0biNRqZ2UpiDxt_0I9JaNdC&index=5).