# Input formats to BLAST

## Multiple sequence alignment

The -in_msa psiblast option provides a way to jump start psiblast from a master-slave multiple sequence alignment computed outside psiblast. The multiple sequence alignment must contain the query sequence as one of its sequences, but it need not be the first sequence. The multiple sequence alignment must be specified in a format that is derived from Clustal, but without some headers and trailers (see example below).

The rules are also described by the following words. Suppose the multiple sequence alignment has N sequences. It may be presented in one or more blocks, where each block presents a range of columns from the multiple sequence alignment. E.g., the first block might have columns 1-60, the second block might have columns 61-95, the third block might have columns 96-128. Each block should have N rows, one row per sequence. The sequences should be in the same order in every block. Blocks are separated by one or more black lines. Within a block there are no blank lines, and each line consists of one sequence identifier followed by some whitespace followed by characters (and gaps) for that sequence in the multiple sequence alignment. In each column, all letters must be in upper case, or all letters must be in lower case.

# Example multiple sequence alignment file align1------26SPS9_Hs     IHAAEEKDWKTAYSYFYEAFEGYdsidspkaitslkymllckimlntpedvqalvsgklaF57B9_Ce      LHAADEKDFKTAFSYFYEAFEGYdsvdekvsaltalkymllckvmldlpdevnsllsaklYDL097c_Sc    ILHCEDKDYKTAFSYFFESFESYhnltthnsyekacqvlkymllskimlnliddvknilnYMJ5_Ce       LYSAEERDYKTSFSYFYEAFEGFasigdkinatsalkymilckimlneteqlagllaakeFUS6_ARATH    KNYIRTRDYCTTTKHIIHMCMNAilvsiemgqfthvtsyvnkaeqnpetlepmvnaklrcCOS41.8_Ci    SLDYKLKTYLTIARLYLEDEDPVqaemyinrasllqnetadeqlqihykvcyarvldyrr644879        KCYSRARDYCTSAKHVINMCLNVikvsvylqnwshvlsyvskaestpeiaeqrgerdsqtYPR108w_Sc    IHCLAVRNFKEAAKLLVDSLATFtsieltsyesiatyasvtglftlertdlkskvidspeeif-3p110_Hs  SKAMKMGDWKTCHSFIINEKMNGkvw----------------------------------T23D8.4_Ce    SKAMLNGDWKKCQDYIVNDKMNQkvw----------------------------------YD95_Sp       IYLMSIRNFSGAADLLLDCMSTFsstellpyydvvryavisgaisldrvdvktkivdspeKIAA0107_Hs   LYCVAIRDFKQAAELFLDTVSTFtsyelmdyktfvtytvyvsmialerpdlrekvikgaeF49C12.8_Hs   LYRMSVRDFAGAADLFLEAVPTFgsyelmtyenlilytvitttfaldrpdlrtkvircneInt-6_Mm      KFQYECGNYSGAAEYLYFFRVLVpatdrnalsslwgklaseilmqnwdaamedltrlket26SPS9_Hs     lryagrqtealkcvaqasknrsladfekaltdy---------------------------F57B9_Ce      alkyngsdldamkaiaaaaqkrslkdfqvafgsf--------------------------YDL097c_Sc    akytketyqsrgidamkavaeaynnrslldfntalkqy----------------------YMJ5_Ce       ivayqkspriiairsmadafrkrslkdfvkalaeh-------------------------FUS6_ARATH    asglahlelkkyklaarkfldvnpelgnsyneviapqdiatygglcalasfdrselkqkvCOS41.8_Ci    kfleaaqrynelsyksaiheteqtkalekalncailapagqqrsrmlatlfkdercqllp644879        qailtklkcaaglaelaarkykqaakclllasfdhcdfpellspsnvaiygglcalatfdYPR108w_Sc    llslisttaalqsissltislyasdyasyfpyllety-----------------------eif-3p110_Hs  ------------------------------------------------------------T23D8.4_Ce    ------------------------------------------------------------YD95_Sp       vlavlpqnesmssleacinslylcdysgffrtladve-----------------------KIAA0107_Hs   ilevlhslpavrqylfslyecrysvffqslavv---------------------------F49C12.8_Hs   vqeqltggglngtlipvreylesyydchydrffiqlaale--------------------Int-6_Mm      idnnsvssplqslqqrtwlihwslfvffnhpkgrdniidlflyqpqylnaiqtmcphilr26SPS9_Hs     ------------------------------------------------------------F57B9_Ce      ------------------------------------------------------------YDL097c_Sc    ------------------------------------------------------------YMJ5_Ce       ------------------------------------------------------------FUS6_ARATH    idninfrnflelvpdvrelindfyssryascleylasl----------------------COS41.8_Ci    sfgilekmfldriiksdemeefar------------------------------------644879        rqelqrnvissssfklflelepqvrdiifkfyeskyasclkmldem--------------YPR108w_Sc    ------------------------------------------------------------eif-3p110_Hs  ------------------------------------------------------------T23D8.4_Ce    ------------------------------------------------------------YD95_Sp       ------------------------------------------------------------KIAA0107_Hs   ------------------------------------------------------------F49C12.8_Hs   ------------------------------------------------------------Int-6_Mm      ylttavitnkdvrkrrqvlkdlvkviqqesytykdpitefveclyvnfdfdgaqkklrec26SPS9_Hs     RAELRDDPIISTHLAKLYDNLLEQNLIRVIEPFSRVQIEHISSLIKLSKADVERKLSQMIF57B9_Ce      PQELQMDPVVRKHFHSLSERMLEKDLCRIIEPYSFVQIEHVAQQIGIDRSKVEKKLSQMIYDL097c_Sc    EKELMGDELTRSHFNALYDTLLESNLCKIIEPFECVEISHISKIIGLDTQQVEGKLSQMIYMJ5_Ce       KIELVEDKVVAVHSQNLERNMLEKEISRVIEPYSEIELSYIARVIGMTVPPVERAIARMIFUS6_ARATH    KSNLLLDIHLHDHVDTLYDQIRKKALIQYTLPFVSVDLSRMADAFKTSVSGLEKELEALICOS41.8_Ci    QLMPHQKAITADGSNILHRAVTEHNLLSASKLYNNIRFTELGALLEIPHQMAEKVASQMI644879        KDNLLLDMYLAPHVRTLYTQIRNRALIQYFSPYVSADMHRMAAAFNTTVAALEDELTQLIYPR108w_Sc    ANVLIPCKYLNRHADFFVREMRRKVYAQLLESYKTLSLKSMASAFGVSVAFLDNDLGKFIeif-3p110_Hs  DLFPEADKVRTMLVRKIQEESLRTYLFTYSSVYDSISMETLSDMFELDLPTVHSIISKMIT23D8.4_Ce    NLFHNAETVKGMVVRRIQEESLRTYLLTYSTVYATVSLKKLADLFELSKKDVHSIISKMIYD95_Sp       VNHLKCDQFLVAHYRYYVREMRRRAYAQLLESYRALSIDSMAASFGVSVDYIDRDLASFIKIAA0107_Hs   EQEMKKDWLFAPHYRYYVREMRIHAYSQLLESYRSLTLGYMAEAFGVGVEFIDQELSRFIF49C12.8_Hs   SERFKFDRYLSPHFNYYSRGMRHRAYEQFLTPYKTVRIDMMAKDFGVSRAFIDRELHRLIInt-6_Mm      ESVLVNDFFLVACLEDFIENARLFIFETFCRIHQCISINMLADKLNMTPEEAERWIVNLI26SPS9_Hs     LDKKFHGILDQGEGVLIIFDEPPF57B9_Ce      LDQKLSGSLDQGEGMLIVFEIAVYDL097c_Sc    LDKIFYGVLDQGNGWLYVYETPNYMJ5_Ce       LDKKLMGSIDQHGDTVVVYPKADFUS6_ARATH    TDNQIQARIDSHNKILYARHADQCOS41.8_Ci    CESRMKGHIDQIDGIVFFERRET644879        LEGLISARVDSHSKILYARDVDQYPR108w_Sc    PNKQLNCVIDRVNGIVETNRPDNeif-3p110_Hs  INEELMASLDQPTQTVVMHRTEPT23D8.4_Ce    IQEELSATLDEPTDCLIMHRVEPYD95_Sp       PDNKLNCVIDRVNGVVFTNRPDEKIAA0107_Hs   AAGRLHCKIDKVNEIVETNRPDSF49C12.8_Hs   ATGQLQCRIDAVNGVIEVNHRDSInt-6_Mm      RNARLDAKIDSKLGHVVMGNNAV