# Privacy

## Privacy Statement

As part of our effort to improve BLAST+, we have implemented usage reporting to collect limited data. This information shows us whether BLAST+ is being used by the community, and therefore is worth being maintained and developed by NCBI. It also allows us to focus our development efforts on the most used aspects of BLAST+. If possible, please report your usage, so we can continue to support and develop BLAST+ to best suit your needs.

You can easily opt-out of sending information about your searches if you wish by following the instructions below (https://www.ncbi.nlm.nih.gov/books/NBK569851/#_intro_Privacy_Optout_of_Usage_Reporting_). This offers you greater privacy control than sending searches over the internet using web tools or the -remote option on a BLAST+ executable, which also accesses the web service.

Information sent back to NCBI is limited to the name of the BLAST program, database metadata, a few BLAST parameters, as well the number and total size of your queries without any data association that might reveal the context of your research. No sequences from your queries or database are sent to the NCBI. An example set of data from a BLAST search is provided below. More information about each item is shown in the table following the list.

IP=27.18.28.18comp_based_stats=2db_date=Aug 26, 2020 3:12 AMdb_length=179658219db_name=swissprotdb_num_seqs=474714evalue_threshold=10.000000exit_status=0hitlist_size=500ncbi_app=standalone-blastncbi_location=be-mdncbi_role=productionnum_queries=1num_threads=2os=UNIXoutput_fmt=11program=blastpqueries_length=656run_time=3.076507task=blastpversion=2.11.0

Reported parameter | Description
IP | The apparent IP address of the machine running BLAST
comp_based_stats | Composition based statistics setting; See Command-line options (https://www.ncbi.nlm.nih.gov/books/NBK279684/#appendices.Options_for_the_commandline_a) in the manual.
db_date | Creation date of the BLAST database
db_length | Length (size) of the database in letters (bases or amino acid characters)
db_name | BLAST database name
db_num_seqs | Number of sequences in the BLAST database.
evalue_threshold | Expect value limit.; See Command-line options (https://www.ncbi.nlm.nih.gov/books/NBK279684/#appendices.Options_for_the_commandline_a)
exit_status | BLAST program exit status. The value ‘0’ indicates success.; See the Exit codes (https://www.ncbi.nlm.nih.gov/books/NBK279684/#appendices.Exit_codes) in the manual for more information.
hitlist_size | Number of matches to return. This is the same value as the max_target_seqs option.; See Command-line options (https://www.ncbi.nlm.nih.gov/books/NBK279684/#appendices.Options_for_the_commandline_a) in the manual.
ncbi_app | Parameter used by NCBI application logging. All BLAST programs return ‘standalone-blast’
ncbi_location | Default parameter for BLAST. Value always ‘be-me for (Bethesda, Maryland)
ncbi_role | Default parameter. Value always production.
num_queries | Number of query sequences in the BLAST search.

## Opt-out of Usage Reporting

You can opt-out of the usage reporting by adding a .ncbirc (UNIX like) or ncbi.ini (Windows) configuration file. In the configuration file you should add a line under the BLAST section to set BLAST_USAGE_REPORT to false. See here (https://www.ncbi.nlm.nih.gov/books/NBK279695/) for details on setting up a configuration file.

You may also opt-out of the usage reporting by setting the environment variable BLAST_USAGE_REPORT to false. In bash (under LINUX) this command would be:

export BLAST_USAGE_REPORT=false

Note that this environment variable is only set in the shell (i.e., window) you are currently using and will not be set the next time you login. To permanently opt-out, this variable should be set every time a new shell is opened or with a configuration file, as described above.

You can also set this environment variable, turning off usage reporting, when using BLAST+ docker by adding the -e option to your docker invocation:

-e BLAST_USAGE_REPORT=false

The NLM privacy policy is available here (https://www.nlm.nih.gov/web_policies.html).