# Dependencies

## Run-time

- For update_blastdb.pl
  - Perl: https://www.perl.org/
- For Windows only:
  - Visual Studio 2015 C++ redistributable runtime package: https://www.microsoft.com/en-us/download/details.aspx?id=48145

## Compile time

These are needed if you are compiling BLAST from source code.

- SQLite (https://gcc02.safelinks.protection.outlook.com/?url=https%3A%2F%2Fwww.sqlite.org%2F&data=05%7C02%7Clisandro.gonzalez%40nih.gov%7C0977619c404c483e51b508dc106f3545%7C14b77578977342d58507251ca2dc2b06%7C0%7C0%7C638403317019519471%7CUnknown%7CTWFpbGZsb3d8eyJWIjoiMC4wLjAwMDAiLCJQIjoiV2luMzIiLCJBTiI6Ik1haWwiLCJXVCI6Mn0%3D%7C3000%7C%7C%7C&sdata=H4mkzg1UpfZjm075zr5fBPJaZDm4zpOCwwY2wiUTqrc%3D&reserved=0): starting with BLAST+ 2.15.0
- LMDB (https://gcc02.safelinks.protection.outlook.com/?url=http%3A%2F%2Fwww.lmdb.tech%2Fdoc%2F&data=05%7C02%7Clisandro.gonzalez%40nih.gov%7C0977619c404c483e51b508dc106f3545%7C14b77578977342d58507251ca2dc2b06%7C0%7C0%7C638403317019519471%7CUnknown%7CTWFpbGZsb3d8eyJWIjoiMC4wLjAwMDAiLCJQIjoiV2luMzIiLCJBTiI6Ik1haWwiLCJXVCI6Mn0%3D%7C3000%7C%7C%7C&sdata=gQUuGLA2ES%2F1UeI5xVFNrMg7J5Mh3A9X5u3tZK89tL0%3D&reserved=0): starting with BLAST+ 2.7.1
- Zstandard (https://gcc02.safelinks.protection.outlook.com/?url=https%3A%2F%2Ffacebook.github.io%2Fzstd%2F&data=05%7C02%7Clisandro.gonzalez%40nih.gov%7C622620752e4a4d556f9308ddc2fc76e0%7C14b77578977342d58507251ca2dc2b06%7C0%7C0%7C638881112049804791%7CUnknown%7CTWFpbGZsb3d8eyJFbXB0eU1hcGkiOnRydWUsIlYiOiIwLjAuMDAwMCIsIlAiOiJXaW4zMiIsIkFOIjoiTWFpbCIsIldUIjoyfQ%3D%3D%7C0%7C%7C%7C&sdata=V6BN7u8XmkrsayGMX1mantadiX5thaZ3CFBQzFnHV%2Bc%3D&reserved=0): starting with BLAST+ 2.17.0
- Bzip2 (https://gcc02.safelinks.protection.outlook.com/?url=https%3A%2F%2Fwww.sourceware.org%2Fbzip2%2F&data=05%7C02%7Clisandro.gonzalez%40nih.gov%7C622620752e4a4d556f9308ddc2fc76e0%7C14b77578977342d58507251ca2dc2b06%7C0%7C0%7C638881112049836953%7CUnknown%7CTWFpbGZsb3d8eyJFbXB0eU1hcGkiOnRydWUsIlYiOiIwLjAuMDAwMCIsIlAiOiJXaW4zMiIsIkFOIjoiTWFpbCIsIldUIjoyfQ%3D%3D%7C0%7C%7C%7C&sdata=mjj%2BX5IzVUnFWKY0IAKEHpVF3xA1tRGNyMpZm3CmJkA%3D&reserved=0): starting with BLAST+ 2.17.0
- Zlib (https://gcc02.safelinks.protection.outlook.com/?url=https%3A%2F%2Fzlib.net%2F&data=05%7C02%7Clisandro.gonzalez%40nih.gov%7Cf4edb80024b340b76fd808ddc4701ce1%7C14b77578977342d58507251ca2dc2b06%7C0%7C0%7C638882708435914691%7CUnknown%7CTWFpbGZsb3d8eyJFbXB0eU1hcGkiOnRydWUsIlYiOiIwLjAuMDAwMCIsIlAiOiJXaW4zMiIsIkFOIjoiTWFpbCIsIldUIjoyfQ%3D%3D%7C0%7C%7C%7C&sdata=z2rpVG365g05A0w82X9x6GgMdUKXQi1M%2FCYh7ANO%2F5s%3D&reserved=0): starting with BLAST+ 2.17.0