# Ignoring the consensus sequence in the multiple sequence alignment in psiblast

Often a consensus sequence is added to a multiple sequence alignment to be used as the master sequence in a PSI-BLAST search. The consensus sequence provides a good option to display the query-subject alignment in the output and to define which MSA columns are to be converted to PSSM. At the same time adding the consensus sequence changes the statistical properties of the original alignment. To avoid this, the -ignore_msa_master option can be used:

psiblast -in_msa align1 -db pataa -ignore_msa_master

In this case the master sequence is displayed in the output but ignored when the PSSM scores are calculated.