# Display BLAST search results with custom output format

The –outfmt option permits formatting arbitrary fields from the BLAST tabular and comma-separated-value (CSV) formats. Use the –help option on the command-line application (e.g., blastn) to see the supported fields. The max_target_seqs option should be used with any tabular output to control the number of matches reported.

## Example of custom output format: field selection

The following example shows how to display the results of a BLAST search using a custom output format. The tabular output format with comments is used, but only the query accession, subject accession, evalue, query start, query stop, subject start, and subject stop are requested. For brevity, only the first 10 lines of output are shown:

$ echo 1786181 | ./blastn -db ecoli -outfmt "7 qacc sacc evalue qstart qend sstart send" # BLASTN 2.2.18+# Query: gi|1786181|gb|AE000111.1|AE000111 # Database: ecoli# Fields: query acc., subject acc., evalue, q. start, q. end, s. start, s. end# 85 hits foundAE000111        AE000111        0.0     1       10596   1       10596AE000111        AE000174        8e-30   5565    5671    6928    6821AE000111        AE000394        1e-27   5587    5671    135     219AE000111        AE000425        6e-26   5587    5671    8552    8468AE000111        AE000171        3e-24   5587    5671    2214    2130$

## Example of custom output format: output separator

One can also customize the output separator in the tabular and comma-separated-value output formats using the delim token immediately after the numeric output format selector. In the example below ‘@’ is used as a custom output separator:

$ echo 1786181 | blastn -db ecoli -outfmt '6 delim=@' | head AE000111.1@AE000111.1@100.000@10596@0@0@1@10596@1@10596@0.0@19568AE000111.1@AE000174.1@88.991@109@9@3@5565@5671@6928@6821@7.69e-30@132AE000111.1@AE000394.1@92.941@85@6@0@5587@5671@135@219@1.29e-27@124AE000111.1@AE000425.1@91.860@86@5@2@5587@5671@8552@8468@5.99e-26@119AE000111.1@AE000171.1@90.588@85@8@0@5587@5671@2214@2130@2.78e-24@113AE000111.1@AE000171.1@90.476@84@8@0@5587@5670@10559@10642@1.00e-23@111AE000111.1@AE000376.1@88.889@90@7@3@5587@5675@129@42@1.30e-22@108AE000111.1@AE000268.1@89.412@85@9@0@5587@5671@6174@6090@1.30e-22@108AE000111.1@AE000112.1@100.000@58@0@0@10539@10596@1@58@1.30e-22@108AE000111.1@AE000447.1@89.286@84@9@0@5587@5670@681@598@4.66e-22@106 $

## Trace-back operations (BTOP)

The “Blast trace-back operations” (BTOP) string describes the alignment produced by BLAST. This string is similar to the CIGAR string produced in SAM format, but there are important differences. BTOP is a more flexible format that lists not only the aligned region but also matches and mismatches. BTOP operations consist of 1.) a number with a count of matching letters, 2.) two letters showing a mismatch (e.g., “AG” means A was replaced by G), or 3.) a dash (“-“) and a letter showing a gap. The box below shows a blastn run first with BTOP output and then the same run with the BLAST report showing the alignments.

$ blastn -query test_q.fa -subject test_s.fa -dust no -outfmt "6 qseqid sseqid btop" -parse_deflinesquery1  q_multi 7AG39query1  q_multi 7A-39query1  q_multi 6-G-A41$ blastn -query test_q.fa -subject test_s.fa -dust no -parse_deflinesBLASTN 2.2.24+Query= query1 Length=47Subject=  Length=142 Score = 82.4 bits (44),  Expect = 9e-22 Identities = 46/47 (97%), Gaps = 0/47 (0%) Strand=Plus/PlusQuery  1   ACGTCCGAGACGCGAGCAGCGAGCAGCAGAGCGACGAGCAGCGACGA  47           ||||||| |||||||||||||||||||||||||||||||||||||||Sbjct  47  ACGTCCGGGACGCGAGCAGCGAGCAGCAGAGCGACGAGCAGCGACGA  93 Score = 80.5 bits (43),  Expect = 3e-21 Identities = 46/47 (97%), Gaps = 1/47 (2%) Strand=Plus/PlusQuery  1   ACGTCCGAGACGCGAGCAGCGAGCAGCAGAGCGACGAGCAGCGACGA  47           ||||||| |||||||||||||||||||||||||||||||||||||||Sbjct  1   ACGTCCG-GACGCGAGCAGCGAGCAGCAGAGCGACGAGCAGCGACGA  46 Score = 78.7 bits (42),  Expect = 1e-20 Identities = 47/49 (95%), Gaps = 2/49 (4%) Strand=Plus/PlusQuery  1    ACGTCC--GAGACGCGAGCAGCGAGCAGCAGAGCGACGAGCAGCGACGA  47            ||||||  |||||||||||||||||||||||||||||||||||||||||Sbjct  94   ACGTCCGAGAGACGCGAGCAGCGAGCAGCAGAGCGACGAGCAGCGACGA  142