# Standalone BLAST Setup for Unix

## Introduction

NCBI provides command line standalone BLAST+ programs (based on the NCBI C++ toolkit) as a single compressed package. The package is available for the Linux, Mac OSX, and Windows platforms at:

https://ftp.ncbi.nlm.nih.gov/blast/executables/LATEST/

The archives for Linux and Mac OSX are available as gzip-compressed tar files named using the following convention:

ncbi-blast-#.#.#+-CHIP-OS.tar.gz

Here, the #.#.# represents the version number of the current release, CHIP indicates the chipset, and OS indicates the operating system. Equivalent .rpm and .dmg files for Linux and Mac OSX are also available. These archives and their target platforms are listed in the table below.

Table 1

Executable BLAST+ package available from NCBI

Archive Name | Content | Chipset | OS | File Type
ncbi-blast-#.#.#+-src.tar.gz | Source code | N/A | N/A | gzip’d tar archive
ncbi-blast-#.#.#+-src.zip | Source code | N/A | N/A | Zipped
ncbi-blast-#.#.#+-win64.exe | Programs | x64 | 64-bit Windows | Windows installer
ncbi-blast-#.#.#+-x64-win64.tar.gz | Programs | x64 | 64-bit Windows | gzip'd tar archive
ncbi-blast-#.#.#+-x64-linux.tar.gz | Programs | x64 | 64-bit Linux | gzip’d tar archive
ncbi-blast-#.#.#+-#.x86_64.rpm | Programs | x64 | 64-bit Linux | Linux RPM package
ncbi-blast-#.#.#+-x64-maxosx.tar.gz | Programs | x64 | 64-bit MacOSX | gzip'd tar archive
ncbi-blast-#.#.#+.dmg | Programs | x64 | 64-bit MaxOSX | Disk image

The installation process from the disk image (.dmg) for Mac OSX and the Red Hat Package Manger (.rpm) for Linux requires administrative privileges and will not be discussed here. More information is available here: http://www.ncbi.nlm.nih.gov/books/NBK569861/.

## Downloading

The BLAST+ packages for various platforms can be downloaded through anonymous ftp using an ftp client, wget, curl, or a web browser. The example working session below demonstrates an ftp download process using an ftp client in a Linux environment. In Mac OSX, a similar command line interface is available through the Terminal utility, which is generally under the Utilities folder.

### Steps

Steps to download the package through a browser are described below.

• Point a browser to this ftp directory: https://ftp.ncbi.nlm.nih.gov/blast/executables/LATEST/

• Right click on a desired archive and select "Save link as…" from the popup menu

• In the prompt, switch to a desired directory (folder) and click the "Save" button to save the selected archive to a desired location on the local disk

### Example

Downloading through an ftp client is shown below with input commands in bold.

$ ncftp ftp.ncbi.nlm.nih.govNcFTP 3.2.5 (Feb 02, 2011) by Mike Gleason (http://www.NcFTP.com/contact/).Connecting to ftp.ncbi.nlm.nih.gov...                                                            This warning banner provides privacy and security notices consistent with  applicable federal laws, directives, and other federal guidance for accessing  this Government system, which includes all devices/storage media attached to  this system. This system is provided for Government-authorized use only.  Unauthorized or improper use of this system is prohibited and may result in  disciplinary action and/or civil and criminal penalties. At any time, and for  any lawful Government purpose, the government may monitor, record, and audit  your system usage and/or intercept, search and seize any communication or data  transiting or stored on this system. Therefore, you have no reasonable  expectation of privacy. Any communication or data transiting or stored on this  system may be disclosed or used for any lawful Government purpose.FTP Server ready.Logging in...                                                                                   Anonymous access granted, restrictions applyLogged in to ftp.ncbi.nlm.nih.gov.                                                              ncftp / > cd /blast/executables/LATEST/  << change directory to the LATESTncftp /blast/executables/LATEST > bin    << set transfer mode to binaryncftp /blast/executables/LATEST > get ncbi-blast-2.10.1+-x64-linux.tar.gzncbi-blast-2.10.1+-x64-linux.tar.gz:                   224.64 MB   37.27 MB/s  ncftp /blast/executables/LATEST > bye$

For platforms lacking a precompiled BLAST+ package, users will need to compile from the BLAST source code. The source code archive, "ncbi-blast-#.#.#+-src" in either zip or gziped tar format, is available from the same LATEST ftp directory. Instructions on compilation are available online in the BLAST+ user manual: http://www.ncbi.nlm.nih.gov/books/NBK279671/#_introduction_Source_tarball, familiarity with compilers is assumed. Questions and feedback on source code compilation should be addressed to:

toolbox@ncbi.nlm.nih.gov

## Installation

To install, simply extract the downloaded package after placing it under a desired directory. This can be accomplished by a single tar command, or a combination of gunzip and tar commands.

$ tar zxvpf ncbi-blast-2.10.1+-x64-linux.tar.gz or$ gunzip -d ncbi-blast-2.10.1+-x64-linux.tar.gz$ tar xvpf ncbi-blast-2.10.1+-x64-linux.tar

Successful execution of the above commands installs the package and generates a new ncbi-blast-2.10.1+ directory under the working directory selected. This new directory contains the bin and doc subdirectories, as well as a set of informational files. The bin subdirectory contains the programs listed below.

Table 2

Programs contained in BLAST+ package

Category | Program | Function
NCBI database downloading tool | update_blastdb.pl | Downloads preformatted blast databases from NCBI
Local database manipulation tools | makeblastdb | Formats input FASTA file(s) into a BLAST database
Local database manipulation tools | makembindex | Indexes an existing nucleotide database for use with megablast for indexed search
Local database manipulation tools | makeprofiledb | Creates a conserved domain database from a list of input position specific scoring matrix (scoremats) generated by psiblast
Local database manipulation tools | dustmasker | Masks the low complexity regions in the input nucleotide sequences, mostly for use in database preparation
Local database manipulation tools | windowmasker | Masks repeats found in input nucleotide sequences
Local database manipulation tools | segmasker | Masks the low complexity regions in input protein sequences, mostly for use in database preparation
Local database manipulation tools | convert2blastmask | Converts lowercase masking into makeblastdb readable data
Local database manipulation tools | blastdb_aliastool | Creates database alias (to tie volumes together, for example)
Local database manipulation tools | blastdbcheck | Checks the integrity of a BLAST database
Local database manipulation tools | blastdbcmd | Retrieves sequences or other information from a BLAST database
Local database manipulation tools | Cleanup-blastdb-volumes.py | Python script to clean up blast database volumes and remove unreferenced volumes [use it with caution and at your own risk!]
Core blast search programs | blastn | Searches a nucleotide query against a nucleotide database
Core blast search programs | blastp | Searches a protein query against a protein database
Core blast search programs | blastx | Searches a nucleotide query, dynamically translated in all six frames, against a protein database
Core blast search programs | tblastn | Searches a protein query against a nucleotide database dynamically translated in all six frames
Core blast search programs | tblastx | Searches a nucleotide query, dynamically translated in all six frames, against a nucleotide database similarly translated
Specialized protein blast search programs | deltablast | Searches a protein query against a protein database, using a more sensitive algorithm
Specialized protein blast search programs | psiblast | Finds members of a protein family, identifies proteins distantly related to the query, or builds position specific scoring matrix for the query
Conserved domain blast search programs | rpsblast | Searches a protein against a conserved domain database to identify functional domains present in the query
Conserved domain blast search programs | rpstblastn | Searches a nucleotide query, by dynamically translating it in all six-frames first, against a conserved domain database
Command line translator | legacy_blast.pl | Converts a legacy blast search command line into blast+ counterpart and execute it
Result formatting tool | blast_formatter | Formats a blast result using its assigned request ID (RID) or its saved archive

## Configuration

Using the BLAST+ package installed above without configuration will be cumbersome – it requires the installation path to be prefixed to the program and database calls since the system does not know where to look for the installed program and the specified database. To streamline BLAST searches, two environment variables, PATH and BLASTDB, need to be modified and created, respectively, to point to the corresponding directories.

Under bash, the following command appends the path to the new BLAST bin directory to the existing PATH setting:

        $ export PATH=$PATH:$HOME/ncbi-blast-2.10.1+/bin

The equivalent command under csh is:

        $ setenv PATH ${PATH}:/home/tao/ncbi-blast-2.10.1+/bin

The modified $PATH can be examined using echo (added portion underlined):

$ echo $PATH/usr/X11R6/bin:/usr/bin:/bin:/usr/local/bin:/opt/local/bin:/home/tao/ncbi-blast-2.10.1+/bin

To manage available BLAST databases, create a directory to store them:

        $ mkdir $HOME/blastdb

Use the approaches described above for PATH to set the BLASTDB value under bash:

        $ export BLASTDB=$HOME/blastdb

Or under csh to create it anew:

        $ set BLASTDB=$HOME/blastdb

A better approach is to have the system automatically set these variables upon login, by modifying the .bash_profile or .cshrc file.

Once they are set, the system knows where to call BLAST programs, and the invoked program will know where to look for the database files. Note that with BLASTDB unspecified, BLAST+ programs only search the working directory, i.e. the directory where BLAST command is issued. For more details about configuring BLAST+, please see https://www.ncbi.nlm.nih.gov/books/NBK569858/.

## Database Download

BLAST database is a key component of any BLAST search. To fully test the BLAST+ package, a functional database is needed. The following working session demonstrates the process of downloading and installing a single-volume database named 16S_ribosomal_RNA from NCBI, using the update_blastdb.pl script included in the /bin directory.

$ cd $HOME/blastdb$ perl ../bin/update_blastdb.pl --passive --decompress 16S_ribosomal_RNAConnected to NCBIDownloading 16S_ribosomal_RNA.tar.gz... [OK]Decompressing 16S_ribosomal_RNA.tar.gz ... [OK]$ ls -l total 172388-rw-r--r-- 1 tao sdesk   1142784 Jun  6 12:05 16S_ribosomal_RNA.ndb-rw-r--r-- 1 tao sdesk   3326945 Jun  6 12:05 16S_ribosomal_RNA.nhr-rw-r--r-- 1 tao sdesk    252508 Jun  6 12:05 16S_ribosomal_RNA.nin-rw-r--r-- 1 tao sdesk    170664 Jun  6 12:05 16S_ribosomal_RNA.nnd-rw-r--r-- 1 tao sdesk       716 Jun  6 12:05 16S_ribosomal_RNA.nni-rw-r--r-- 1 tao sdesk     84152 Jun  6 12:05 16S_ribosomal_RNA.nog-rw-r--r-- 1 tao sdesk    424244 Jun  6 12:05 16S_ribosomal_RNA.nos-rw-r--r-- 1 tao sdesk    252764 Jun  6 12:05 16S_ribosomal_RNA.not-rw-r--r-- 1 tao sdesk   7761701 Jun  6 12:05 16S_ribosomal_RNA.nsq-rw-r--r-- 1 tao sdesk    548864 Jun  6 12:05 16S_ribosomal_RNA.ntf-rw-r--r-- 1 tao sdesk    148812 Jun  6 12:05 16S_ribosomal_RNA.nto-rw-r--r-- 1 tao sdesk        59 Jun 11 12:14 16S_ribosomal_RNA.tar.gz.md5-rw-r--r-- 1 tao sdesk 146879591 Jun  6 12:05 taxdb.btd-rw-r--r-- 1 tao sdesk  15506928 Jun  6 12:05 taxdb.bti$

For databases with multiple volumes, update_blastdb.pl will automatically get all of them. For databases already installed locally, update_blastdb.pl will compare it against that on the NCBI ftp site to determine if refreshing is needed.

$ perl ../bin/update_blastdb.pl --passive --decompress 16S_ribosomal_RNAConnected to NCBIThe contents of 16S_ribosomal_RNA.tar.gz are up to date in your system.$

## Execution and validation

With the above configuration, BLAST programs installed under the "ncbi-blast-2.10.1+/bin" directory can be invoked by name from any directory. Type the command "blastn -help" (without quotes) should display the program parameters of blastn in the console as shown below.

$ blastn -helpUSAGE  blastn [-h] [-help] [-import_search_strategy filename]    [-export_search_strategy filename] [-task task_name] [-db database_name]    [-dbsize num_letters] [-gilist filename] [-seqidlist filename]    [-negative_gilist filename] [-entrez_query entrez_query]    [-db_soft_mask filtering_algorithm] [-db_hard_mask filtering_algorithm]    [-subject subject_input_file] [-subject_loc range] [-query input_file]    [-out output_file] [-evalue evalue] [-word_size int_value]    [-gapopen open_penalty] [-gapextend extend_penalty]    [-perc_identity float_value] [-xdrop_ungap float_value]    [-xdrop_gap float_value] [-xdrop_gap_final float_value]    [-searchsp int_value] [-max_hsps int_value] [-sum_statistics]    [-penalty penalty] [-reward reward] [-no_greedy]    [-min_raw_gapped_score int_value] [-template_type type]    [-template_length int_value] [-dust DUST_options]    [-filtering_db filtering_database]    [-window_masker_taxid window_masker_taxid]    [-window_masker_db window_masker_db] [-soft_masking soft_masking]    [-ungapped] [-culling_limit int_value] [-best_hit_overhang float_value]    [-best_hit_score_edge float_value] [-window_size int_value]    [-off_diagonal_range int_value] [-use_index boolean] [-index_name string]    [-lcase_masking] [-query_loc range] [-strand strand] [-parse_deflines]    [-outfmt format] [-show_gis] [-num_descriptions int_value]    [-num_alignments int_value] [-html] [-max_target_seqs num_sequences]    [-num_threads int_value] [-remote] [-version]DESCRIPTION   Nucleotide-Nucleotide BLAST 2.2.29+OPTIONAL ARGUMENTS -h   Print USAGE and DESCRIPTION;  ignore all other parameters -help   Print USAGE, DESCRIPTION and ARGUMENTS; ignore all other parameters -version   Print version number;  ignore other arguments *** Input query options -query <File_In>   Input file name   Default = `-' -query_loc <String>   Location on the query sequence in 1-based offsets (Format: start-stop) -strand <String, `both', `minus', `plus'>   Query strand(s) to search against database/subject   Default = `both'...

For installation without $PATH modification, prefix the path to the program. For example, to execute the same command from /home/tao directory, use the following command instead, where the "./" prefix denotes the current working directory:

/home/tao $ ./ncbi-blast-2.10.1+/bin/blastn –help

### Example Execution

The real test of this installation should be example searches. The working session shown below performs the following task:

- Call blastdbcmd to extract the sequence of NR_025000 from the installed database (16S_ribosomal_RNA) to a text file (16S_query.fa)
- Run a blastn search using the sequence in test_query.fa as query against the 16S_ribosomal_RNA database
- With extra custom settings of using blastn algorithm (-task blastn), without filter (-dust no), requesting custom tabular output (-outfmt “7 delim=. Etc), and asking only for the top 5 hits (-max_target_seqs 5)
- Since no -out is specified, the result is displayed in the console (starting from the # initialed line)

          $ blastdbcmd -db 16S_ribosomal_RNA -entry nr_025000 -out 16S_query.fa
          
          
          $ blastn -db 16S_ribosomal_RNA -query 16S_query.fa -task blastn -dust no -outfmt "7 delim=, qacc sacc evalue bitscore qcovus pident" -max_target_seqs 5
          
          
          # BLASTN 2.10.1+
          
          # Query: NR_025000.1 Mycobacterium kubicae strain CDC 941078 16S ribosomal RNA, partial sequence
          
          # Database: 16S_ribosomal_RNA
          
          # Fields: query acc., subject acc., evalue, bit score, % query coverage per uniq subject, % identity
          
          # 5 hits found
          
          NR_025000.1,NR_025000,0.0,2383,100,100.000
          
          NR_025000.1,NR_028940,0.0,2334,100,99.243
          
          NR_025000.1,NR_125568,0.0,2320,100,98.940
          
          NR_025000.1,NR_118110,0.0,2302,100,98.637
          
          NR_025000.1,NR_117220,0.0,2302,100,98.637
          
          # BLAST processed 1 queries
          
          
          $

Note that the command lines and output wrap around.

## Technical Assistance

Questions, feedback, and technical assistance requests should be sent to blast-help at:

blast-help@ncbi.nlm.nih.gov

Questions on other NCBI resources should be addressed to NCBI User Services at:

info@ncbi.nlm.nih.gov