# Preface

Health, United States, 2017 is the 41st report on the health status of the country, and is submitted by the Secretary of the U.S. Department of Health and Human Services to the President and the Congress of the United States in compliance with Section 308 of the Public Health Service Act. This report was compiled by the Centers for Disease Control and Prevention’s (CDC) National Center for Health Statistics (NCHS).

The Health, United States series presents an annual overview of national trends in health statistics. The report contains a Chartbook that presents trends and current information on selected measures of morbidity, mortality, health care utilization and access, health risk factors, prevention, health insurance, and personal health care expenditures. The Chartbook includes a Special Feature section, which examines a topic of public health interest and policy relevance.

In addition to the Chartbook, Health, United States, 2017 provides 114 Trend Tables organized around four subject areas: health status and determinants, health care utilization, health care resources, and health care expenditures. The Trend Tables, along with the other components of Health, United States, 2017, are available for download on the Health, United States website at: https://www.cdc.gov/nchs/hus/index.htm.

## The 2017 Edition

Health, United States, 2017 contains a summary At a Glance table that displays recent data on selected indicators of health and their determinants, cross-referenced to tables in the report. This is followed by a Highlights section, which focuses on both trends during the past decade and current data on topics of public health interest, illustrating the breadth of material included in Health, United States. The remaining major sections are a Chartbook, detailed Trend Tables, two Appendixes, and an Index. These sections of the 2017 report are described in detail below.

### Chartbook

The 2017 Chartbook contains 30 figures on health status and determinants, health care utilization, health care resources, and health care expenditures (Figures 1–19), as well as 11 figures focusing on mortality (Figures 20–30). The Special Feature on Mortality examines when, why, and where individuals are dying in the United States. Data on life expectancy at birth are presented by sex, followed by data on death rates by age group. Leading causes of death for each age group are explored to describe mortality trends from infancy to old age. The Special Feature also examines three causes of death that have contributed to life expectancy losses in recent years: drug overdoses, suicides, and chronic liver disease. Finally, changes over time in estimates of place of death are presented.

### Trend Tables

This edition includes 114 detailed Trend Tables that highlight major trends in health statistics in the four areas: health status and determinants, health care utilization, health care resources, and health care expenditures. These include an expanded table on mortality from drug overdoses (Table 27) and a table with a new measure of functional limitation (Table 42). An important criterion used in selecting trend tables is the availability of comparable national data over a period of several years. The Trend Tables for Health, United States, 2017 are available for download at: https://www.cdc.gov/nchs/hus/contents2017.htm.

### Appendixes

Appendix I. Data Sources describes each data source used in Health, United States, 2017, as well as provides references for further information about the sources. Data sources are listed alphabetically within two broad categories: Government Sources and Private and Global Sources.

Appendix II. Definitions and Methods includes selected terms used in Health, United States, 2017. It also contains information on the statistical methodologies used in the report.

The Appendixes for Health, United States, 2017 are available for download at: https://www.cdc.gov/nchs/hus/appendix.htm.

### Index and Search Features

The Index to the Trend Tables and Chartbook figures is a useful tool for locating data by topic. The Data Finder, a companion search tool is available on the Health, United States website to help users narrow down the list of tables and charts by health topic and populations of interest. Topics include areas such as drug overdose, injury, and functional limitation. Populations include groups such as children and adolescents, American Indian or Alaska Native persons, and those living in specific geographic regions. See the Health, United States, 2017 Data Finder at: https://www.cdc.gov/nchs/hus/contents2017.htm.

## Data Considerations

### Racial and Ethnic Data

Many tables in Health, United States present data according to race and Hispanic origin, consistent with a department-wide emphasis on ensuring that health data on racial and ethnic minority populations are presented whenever possible. Trend data on race and ethnicity are presented in the greatest detail possible after taking into account the quality of the data, the amount of missing data, and the number of observations. These issues significantly affect the availability of reportable data for certain populations, such as the Native Hawaiian or Other Pacific Islander populations and the American Indian or Alaska Native populations. Standards for the classification of federal data on race and ethnicity are described in Appendix II. (See Appendix II, Race.)

### Education and Income Data

Many Trend Tables in Health, United States present data according to socioeconomic status, using education and family income as proxy measures. Education and income data are generally obtained directly from survey respondents and are not usually available from records-based data collection systems. (See Appendix II, Education; Family income; Poverty.)

### Statistical Significance

All statements in the text describing differences, or lack thereof, in estimates indicate that statistical testing was performed. Differences between two point estimates were determined to be statistically significant at the 0.05 level using two-sided significance tests (z-tests) without correction for multiple comparisons. Data tables include point estimates and standard errors for users who would like to perform statistical tests. In the text, the standard terminology used when a difference between two point estimates was tested is, “Between (estimate 1) and (estimate 2).” For example, the statement “Between 2015 and 2016” indicates that the difference between the point estimate for 2015 and that for 2016 was tested for statistical significance.

Data trends can be analyzed in many ways. The approaches used in Health, United States, 2017 to analyze trends in health measures depend on the data source, the unit of analysis, and the number of data points. (For a description of the trend testing technique, see the Technical Notes that follow the Chartbook.) The statement “During 2006–2016” indicates that a statistical test of trend was conducted, which included estimates for all 11 years in the time period. Because statistically significant differences or trends are partly a function of sample size (i.e., the larger the sample, the smaller the change that can be detected), statistically significant differences or trends do not necessarily have public health significance (1).

Terms such as “similar,” “stable,” and “no difference” indicate that the statistics being compared were not significantly different. Lack of comment regarding the difference between statistics does not necessarily suggest that the difference was tested and found to not be significant.

National estimates generally have relatively small standard errors, but estimates for certain population subgroups may be based on small numbers and have relatively large standard errors. Although the number of births and deaths from the Vital Statistics System represent complete counts (except for births in those states where data are based on a 50% sample for selected years) and are not subject to sampling error, the counts are subject to random variation, which means that the number of events that actually occur in a given year may be considered as one of a large series of possible results that could have arisen under the same circumstances. When the number of events is small and the probability of such an event is small, considerable caution must be observed in interpreting the conditions described by the estimates. Estimates that are unreliable because of large standard errors or small numbers of events are noted with an asterisk. The criteria used to designate or suppress unreliable estimates are indicated in the table footnotes.

For NCHS surveys, point estimates and their corresponding variances were calculated using the SUDAAN software package (2), which takes into consideration the complex survey design. Starting with Health, United States, 2017, the reliability of survey percentage estimates was assessed using a new method (3). Standard errors are available for selected tables in the spreadsheet version on the Health, United States website at: https://www.cdc.gov/nchs/hus/contents2017.htm. (See Appendix II, Data presentation standards; Relative standard error [RSE].)

## Accessing Health, United States

Health, United States, 2017 can be accessed in its entirety at: https://www.cdc.gov/nchs/hus/index.htm. The website is a user-friendly resource for Health, United States and related products. The Chartbook figures are provided as PowerPoint slides, and the Trend Tables and Chartbook data tables are provided as spreadsheet and PDF files. Many spreadsheet files include additional years of data not shown in the PDF files, along with standard errors, where available. Visitors to the website can join the Health, United States e-mail list (https://www.cdc.gov/nchs/hus/hus_electronic_mailing.htm) to receive announcements about release dates and notices of updates. Previous editions of Health, United States and its Chartbooks can also be accessed from the website.

Printed copies of Health, United States can be purchased from the U.S. Government Printing Office at: https://bookstore.gpo.gov.

## Questions?

If you have questions about Health, United States or related data products, please contact:

- Office of Information Services
  Information Dissemination Staff
  National Center for Health Statistics
  Centers for Disease Control and Prevention
  3311 Toledo Road
  Hyattsville, MD 20782–2064
  Phone: 1–800–CDC–INFO (1–800–232–4636)
  TTY: 1–888–232–6348
  Internet: https://www.cdc.gov/nchs
  Online request form: https://www.cdc.gov/cdc-info/requestform.html

For e-mail updates on NCHS publication releases, subscribe online at: https://www.cdc.gov/nchs/govdelivery.htm.

## References

1 Ingram DD, Malec DJ, Makuc DM, Kruszon-Moran D, Gindi RM, Albert M, National Center for Health Statistics Guidelines for Analysis of Trends. National Center for Health Statistics. Vital Health Stat 2(179). 2018.
2 SUDAAN, release 11.0.0 [computer software]. Research Triangle Park, NC: RTI International; 2012.
3 Parker JD, Talih M, Malec DJ, National Center for Health Statistics Data Presentation Standards for Proportions. National Center for Health Statistics. Vital Health Stat 2(175). 2017.